# Discussion

## Key Findings and Strength of Evidence

In this Comparative Effectiveness Review (CER), we reviewed 21 studies involving 4,346 patients that evaluated attentional deficit hyperactivity disorder (ADHD) diagnostic strategies for children and adolescents that could be used in the primary care setting and evaluated the impact of being labeled as having ADHD (Key Question [KQ] 1) and 69 studies involving 14,737 patients to evaluate the comparative effectiveness of different pharmacologic and nonpharmacologic therapies for ADHD (KQ 2). Because of variations in “usual care” often used as the comparator, detailed descriptions of the comparator were made and considered in the evaluation of the available evidence. We hoped to evaluate the comparative effectiveness of different follow-up strategies for children and adolescents with ADHD (KQ 3). However, no study was identified that met the criteria for inclusion.

### KQ 1 ADHD Diagnosis

This review focused on evidence evaluating diagnosis in children under 7 years of age or for older children (up to 17 years of age) using novel diagnostic techniques including imaging, electroencephalography (EEG), or assessment of executive function. The strength of evidence (SOE) was insufficient to evaluate the validity of diagnostic approaches for children under 7 years. The Attention and Executive Function Rating Inventory and Childhood Executive Functioning Inventory performed better than the Cambridge Neuropsychological Test Automated Battery for the diagnosis of ADHD in children and adolescents 7 through 17 years of age (strength of evidence [SOE]=low).

Limited information was found regarding the harm of being labeled with ADHD. Only two cross-sectional studies were evaluated, and they only assessed the perspective of parents and teachers. Neither study directly assessed the experience of children or adolescents with ADHD. Therefore, no conclusions could be drawn regarding the impact of ADHD diagnosis.

### KQ 2 ADHD Treatment

ADHD treatment options include pharmacologic and nonpharmacologic therapies. The 2011 AHRQ report highlighted the benefit of psychostimulants for children 6 through 12 years of age and the potential benefit of additional behavior therapy, especially for those with oppositional defiant disorder. For younger children, the 2011 AHRQ report found parent behavioral interventions to be effective

Atomoxetine and MPH were the most common drugs evaluated in the studies included in this review (evaluated in 8 studies). The SOE was insufficient to determine which drug is more effective or whether the side-effect profiles are different. There was also little evidence regarding serious cardiovascular risk with use of these medications.

Of the nonpharmacologic therapies, the SOE since the last review was insufficient to evaluate neurofeedback. Studies since the last review found that child or parent training appear to improve standardized ADHD symptom scores (SOE=moderate) but had no difference in academic performance (SOE=low). Cognitive training and cognitive behavioral therapy was associated with improved standardized symptoms scores (SOE=low each).

The most well-studied nutritional therapy is dietary supplementation with omega-3/6 fatty acids. However, based on our meta-analysis, there was no impact of omega-3/6 supplements on parent or teacher rating scales of ADHD symptoms.

Table 20 summarizes the SOE findings for KQ 2 that were graded as low, moderate, or high.

Table 20 Summary strength of evidence for major outcomes for KQ 2

Outcome | No. Studies/Design (N Patients) Age Category | Findings | SOE Grade
Pharmacologic vs. Placebo Treatments: NA
Pharmacologic vs. Pharmacologic Treatments
Gastrointestinal symptoms | 3 Obs (1,966) 7–17 | Atomoxetine has slightly higher GI effects or disease than MPH.^121, 123, 151^ | Low
Pharmacologic vs. Nonpharmacologic Treatments
Changes in appetite | 3 RCTs (212) 7–17 | MPH decreased appetite compared to ningdong, omega-3/6 or gingko biloba.^114, 141, 155^ | Low
Sleep disturbance | 4 RCTs (324) 7–17 | MPH resulted in increased sleep disturbances compared to ningdong, gingko biloba, omega-3/6, or neurofeedback.^114, 141, 155^ | Low
Nonpharmacologic vs. Nonpharmacologic or Other Treatments
Neurofeedback: NA
Cognitive Training
Changes in standardized symptom scores | 9 RCTs (768) 7–17, all through 17 | There is some evidence that cognitive training strategies such as the computer-based Cogmed cognitive training program may reduce ADHD symptoms in the short term but not the long term.^115, 119, 122, 126, 132, 160, 163, 174^ | Low
Cognitive Behavioral Therapy
Changes in standardized symptoms scores | 2 RCTs (278) 7–17 | CBT improved ADHD symptoms relative to usual care or a limited CBT intervention.^117, 164^ | Low
Child or Parent Training or Behavioral
Changes in standardized symptom scores | 8 RCTs, 1 Obs (966) 7–17 | ADHD symptoms were significantly improved with child or parent training, sleep hygiene, or behavioral interventions.^112, 127, 129, 138, 150, 152, 167–169, 184^ | Moderate
Academic performance | 2 RCTs (356) 7–17 | There were no differences in academic performance associated with organizational skills or social skills training relative to no intervention.^108, 161^ | Low
Omega-3 Supplementation
Changes in standardized symptom scores | 7 RCTs (795) 7–17 | Omega-3/6 did not improve parent ratings compared to placebo (SMD −0.32, 95% CI −0.80 to 0.15) or teacher ] (SMD −0.08, 95% CI −0.47 to 0.32).^133, 136, 139, 142, 143, 154, 190, 191, 195^ | Moderate
Herbal Interventions or Dietary Approaches
Changes in standardized symptom scores | 3 RCTs (238) 7–17, all through 17 | ADHD-RS scores improved with an elimination diet relative to a nonrestricted diet, while ADHD symptoms were not reduced with either Memomet syrup or zinc supplementation relative to placebo.^111, 125, 172^ | Low
Other Approaches
Academic performance | 3 RCTs (586) 7–17, all through 17 | Neither the Challenging Horizons Program-After School version nor the Family School Success-Early Elementary interventions improved academic performance.^128, 153, 170^ | Low

Abbreviations: ADHD=attention deficit hyperactivity disorder; CBT=cognitive behavioral therapy; GI=gastrointestinal; Obs=observational; RCT=randomized controlled trial; RS=rating scale; SMD=standardized mean difference; SOE=strength of evidence

## Findings in Relation to What Is Already Known

Table 21 summarizes the differences and similarities in scope across this current systematic review compared with the 2011 review,^4^ along with our main findings.

Table 21 Differences in scope between the 2011 and current evidence reports

| 2011 Report | Current Report
Key Questions (KQs) | This systematic review compared effectiveness and adverse events of interventions for preschoolers at high risk for ADHD; compared long-term effectiveness and adverse events of interventions for ADHD among persons of all ages; and described how identification and treatment for ADHD varied. Specifically, the KQs included:; 1. Among children younger than 6 years of age with ADHD or disruptive behavior disorders, what are the effectiveness and adverse event outcomes following treatment?; 2. Among people 6 years of age or older with ADHD, what are the effectiveness and adverse event outcomes following 12 months or more of any combination of followup or treatment, including, but not limited to, 12 months or more of continuous treatment?; 3. How do (a) underlying prevalence of ADHD and (b) rates of diagnosis (clinical identification) and treatment for ADHD vary by geography, time period, provider type, and sociodemographic characteristics? | This systematic review updates and extends two previous systematic evidence reviews and focuses on the comparative effectiveness of methods to establish the diagnosis of ADHD, updates the comparative effectiveness of pharmacologic and nonpharmacologic treatments, and evaluates different monitoring strategies in the primary care setting for individuals from birth through 17 years of age. Specifically, the KQs include:; 1. For the diagnosis of ADHD:; a. What is the comparative diagnostic accuracy of approaches that can be used in the primary care practice setting or by specialists to diagnose ADHD among individuals younger than 7 years of age?; b. What is the comparative diagnostic accuracy of EEG, imaging, or executive function approaches that can be used in the primary care practice setting or by specialists to diagnose ADHD among individuals aged 7 through 17?; c. For both populations, how does the comparative diagnostic accuracy of these approaches vary by clinical setting, including primary care or specialty clinic, or patient subgroup, including age, sex, or other risk factors associated with ADHD?; d. What are the adverse effects associated with being labeled correctly or incorrectly as having ADHD?; 2. What are the comparative safety and effectiveness of pharmacologic and/or nonpharmacologic treatments of ADHD in improving outcomes associated with ADHD? How do these outcomes vary by presentation (inattentive, hyperactive/impulsive, and combined) or other comorbid conditions? What is the risk of diversion of pharmacologic treatment?; 3. What are the comparative safety and effectiveness of different monitoring strategies to evaluate the effectiveness of treatment or changes in ADHD status (e.g., worsening or resolving symptoms)?
Publication dates for included studies | By KQ:; 1. Inception to 2010; 2. 1997–2010; 3. 1980–2010 | 2009–2016
ADHD diagnosis | Not addressed | The Attention and Executive Function Rating Inventory and Childhood Executive Functioning Inventory performed better than the Cambridge Neuropsychological Test Automated Battery for the diagnosis of ADHD between 7 and 17 years of age (SOE=low). This systematic evidence review identified limited studies with variable and inconsistent findings for diagnostic accuracy for all other diagnostics tools evaluated, including imagining and EEG-based tests
Treatment of preschoolers with disruptive behavior disorders, including those at risk of ADHD | Evidence favored treatment with parent behavior training. Only one good-quality study of the effectiveness of methylphenidate (MPH) was identified, which found therapy to be effective. | Not addressed
Long-term effectiveness and safety of treatment in people aged 6 and older | - MPH is effective for ADHD treatment for 14 months and atomoxetine (ATX) for over 12 months. SOE was low.; - Combining medication and behavioral treatment can improve outcome compared to medication alone for some outcomes for those with ADHD combined type. SOE was low and the population were not necessarily formally diagnosed with ADHD. | - There are no new conclusions regarding the effectiveness of pharmacotherapy vs. placebo, of comparing different pharmacologic treatments, or of comparing combined therapeutic approaches (i.e., pharmacotherapy and nonpharmacotherapy).; - Gastrointestinal side effects are slightly higher for ATX compared with MPH; however, the SOE was low.; - Compared with placebo, child or parent training can improve ADHD symptoms. SOE was moderate. It did not however improve academic performance (SOE low) There are still questions related to the comparative effectiveness with pharmacotherapy alone or in combination with behavioral therapy.; - Compared with placebo, omega-3 fatty acid supplementation had no difference on ADHD symptoms. SOE was moderate.; - Cognitive behavioral therapy improved ADHD symptom scores. SOE was low
Prevalence and variations in diagnosis and treatment | There is significant variation in diagnosis and treatment, with an overall increase in the use of pharmacotherapy. | Not addressed
Monitoring strategies | Not addressed | There were no studies found that compared monitoring strategies after the diagnosis of ADHD.

Abbreviations: ADHD=attention deficit hyperactivity disorder; ATX=atomoxetine; EEG=electroencephalography; KQ=Key Question; MPH=methylphenidate; SOE=strength of evidence

Since publication of the American Academy of Pediatrics (AAP) clinical practice guideline, there has been significant interest in the use of objective tests that could overcome the inherent limitations in the use of behavioral rating scales. Our systematic review could not find sufficient evidence to recommend that such tests now be incorporated into care, although the review was limited to studies published in 2009 and later. The AAP guideline also recognized the potential harm of labeling an individual with ADHD, but our review did not identify studies that would allow an estimate of this potential harm.

The AAP clinical practice guideline, based on the 2011 review, recommends behavioral therapy for children 4 through 5 years of age as the first line of therapy, with consideration of methylphenidate (MPH) if such interventions fail. In contrast, the AAP preferably recommends Food and Drug Administration (FDA)-approved medications and behavioral interventions for older children and adolescents. A recent Cochrane review of randomized controlled trials for the treatment of ADHD found that although MPH might improve ADHD symptoms, the level of certainty was low because most trials were underpowered, of low quality, and had short duration of follow-up.^77^ That review included studies of children and adolescents 18 years and younger with ADHD according to DSM 3, 4, or 5 published by March 2015. Another systematic review supported the use of MPH, atomoxetine, and extended-release guanfacine to improve ADHD symptoms in adolescents.^70^ That review only included studies of subjects 12–18 years of age published from 1999 through January 2016. As with the Cochrane review,^77^ limitations in study quality were identified.

Our systematic review was not able to provide further evidence regarding the comparative effectiveness of FDA-approved medications. Other than omega-3 supplements which had moderate SOE for no difference in ADHD symptom scores, none of the other dietary supplements for ADHD therapy has sufficient SOE. However, the behavioral interventions were of did demonstrate effectiveness based on the studies included in this update. We found low SOE for cognitive behavioral therapy and moderate SOE for child or parent training but no difference in academic performance (SOE=low). Insufficient data were available to determine whether there is a subgroup of children and adolescents with ADHD (e.g., based on age or other characteristics) for whom these therapies might be more effective.

No existing systematic reviews or guidelines address the frequency that children or adolescents receiving care for ADHD should receive follow-up in the primary care practice setting or what approach should be used for monitoring after treatment is begun. Unfortunately, our systematic review also found no information to inform this question.

Prior to the publication of the AAP clinical practice guideline, the American Academy of Child and Adolescent Psychiatry released recommendations for establishing the diagnosis of ADHD and treating the condition.^216^ These recommendations were consistent with the AAP clinical practice guideline, including the need for a comprehensive evaluation to establish the diagnosis and the need to personalize therapy, using behavioral interventions and/or stimulant therapy. Since the publication of the AAP clinical practice guideline, the American Academy of Neurology has released a guideline recommending against the use of EEG to confirm ADHD or to support further testing within the context of usual clinical care.^217^ The 2011 review did not address approaches to diagnosis. The current review did not find sufficient evidence to recommend for or against the use of EEGs to confirm ADHD.

## Applicability

The accuracy of diagnostic tests and the effects of interventions for ADHD as determined in clinical studies do not always translate well to usual practice, where patient characteristics, clinical training, and resources may differ from study conditions in key ways. In addition, the availability of ADHD interventions studied in our review may differ from those easily available to patients within the United States.

For our analysis of diagnostic tools, study participants were generally adequately described. The main issue affecting applicability was the source of patients, who were selected from specialty clinics. This might affect the reported test characteristics (e.g., sensitivity and specificity). In general, given the scarcity of evidence we were not able to separately consider the role of age, ADHD subtype, or prior therapy. Most studies of diagnostic tools are performed outside of the primary care practice setting, further limiting applicability to children seen in the primary care setting. The studies of labeling have low applicability because they did not address specific patients or were surveys based on hypothetical children labeled with having ADHD.

The treatment studies we evaluated have moderate applicability due to significant heterogeneity regarding the duration of therapy, the study population, and the follow-up period. However, there was consistency in findings related to pharmacotherapy.

We were unable to find any studies that met the inclusion criteria regarding follow-up after treatment initiation (KQ 3).

Table 22 shows potential issues with applicability for studies included for KQ 1. Table 23 shows similar information for studies included in KQ 2 and is broken down by type of intervention.

Table 22 Potential issues with applicability of included studies for Key Question 1

Issue | N=21 Studies
Population (P)
Narrow eligibility criteria and exclusion of those with comorbidities | 2
More complex patients than typical of the community | 2
Run-in period with high exclusion rate for non-adherence or side effects | 0
DSM-4/5 diagnosis unclear | 0
Intervention (I)
Diagnostic tools used differently than as recommended or commonly used in practice | 0
Dosing not reflective of current practice | 0
Co-interventions that are likely to modify the effectiveness of therapy | 0
Highly selected intervention team or level of training/proficiency not widely available | 1
Follow-up not reflective of current practice | 0
Co-intervention that are likely to modify monitoring strategies | 0
Comparator (C)
Diagnostic tools used differently than as recommended or commonly used in practice | 0
Comparator unclear | 0
Inadequate comparison therapy or use of a substandard alternative therapy | 0
Outcomes (O)
Composite outcomes that mix outcomes of different significance | 0
Short-term follow-up | 0
Surrogate outcomes | 0
Setting (S)
Level of care different from that in the community | 9

DSM=Diagnostic and Statistical Manual of Mental Disorders

Table 23 Potential issues with applicability of included studies for Key Question 2

Issue | N=69 Studies
Issue | Pharm vs. Pharm N=9 | Pharm vs. Nonpharm N=7 | Pharm vs. Placebo N=7 | Nonpharm vs. Nonpharm N=15 | Nonpharm vs. Placebo N=37
Population (P)
Narrow eligibility criteria and exclusion of those with comorbidities | 0 | 0 | 1 | 2 | 1
More complex patients than typical of the community | 0 | 0 | 0 | 0 | 0
Run-in period with high exclusion rate for non-adherence or side effects | 0 | 0 | 0 | 0 | 0
DSM-4/5 diagnosis unclear | 0 | 0 | 0 | 0 | 1
Intervention (I)
Diagnostic tools used differently than as recommended or commonly used in practice | 0 | 0 | 0 | 0 | 0
Dosing not reflective of current practice | 0 | 0 | 0 | 0 | 0
Co-interventions that are likely to modify the effectiveness of therapy | 1 | 1 | 2 | 0 | 4
Highly selected intervention team or level of training/proficiency not widely available | 0 | 1 | 1 | 1 | 4
Follow-up not reflective of current practice | 0 | 0 | 1 | 0 | 1
Co-intervention that are likely to modify monitoring strategies | 0 | 0 | 0 | 0 | 0
Comparator (C)
Diagnostic tools used differently than as recommended or commonly used in practice | 0 | 0 | 0 | 0 | 0
Comparator unclear | 1 | 0 | 1 | 0 | 0
Inadequate comparison therapy or use of a substandard alternative therapy | 1 | 0 | 0 | 1 | 3
Outcomes (O)
Composite outcomes that mix outcomes of different significance | 0 | 0 | 0 | 0 | 0
Short-term follow-up | 0 | 2 | 1 | 4 | 10
Surrogate outcomes | 0 | 0 | 0 | 0 | 0
Setting (S)
Level of care different from that in the community | 0 | 1 | 2 | 2 | 4

Abbreviations: DSM=Diagnostic and Statistical Manual of Mental Disorders; Pharm=pharmacologic; Nonpharm=nonpharmacologic

## Implications for Clinical and Policy Decisionmaking

The lack of strong evidence for objective tests for the diagnosis of ADHD suggests that behavior rating scales should continue to be used as the primary strategy for diagnosing the condition. Overall, pharmacotherapy has been more studied than other treatment approaches and is generally considered the first approach to treatment for children and adolescents over 7 years of age. Insufficient data were available to determine whether they should be the first line of therapy for children under 7 years of age. Cognitive behavioral therapy (low SOE) or child or parent training (moderate SOE) may reduce symptoms of ADHD but had no difference in academic performance (low SOE). Insufficient data were available to evaluate the effect of combining medication therapy with these approaches to care. There is a lack of supportive data for other complementary therapies. Although regular follow-up is recommended for children and adolescents with ADHD, no evidence was found about the comparative benefits and harms of different approaches.

## Limitations of the Systematic Review Process

Our findings have limitations related to the literature and our approach. Important limitations of the literature include (1) population heterogeneity; (2) short follow-up periods; (3) small sample sizes; (4) studies conducted outside of primary care; (5) variability in outcomes to assess efficacy and tolerability; and (6) inconsistent reporting of comparative statistical analyses.

Our review methods also have limitations. This review was designed to extend two previous systematic reviews.^4, 19^ However, these two previous reviews did not have the same focus on issues related to the diagnosis and management of ADHD as this review. The time period of this systematic review led to the exclusion of earlier larger studies. In addition, some of the earlier reports regarding studies (e.g., the Multisite Multimodal Treatment Study of Children with ADHD [MTA]) included in this review might have been excluded. Our study was limited to English-language publications. Note that during the protocol development phase of our review we made two scoping revisions in consultation with our Technical Expert Panel (TEP). Specifically the review focused on:

- KQ 1: Diagnostic methods in children aged 6 or under or which compared novel diagnostic methods (e.g., imaging or EEG)
- KQ 2: Studies comparing two or more pharmacologic treatments approved by the FDA for the treatment of ADHD needed include 100 or more patients with ADHD and have a followup period of 6 months or longer. Criteria were less stringent for studies assessing nonpharmacologic treatments or pharmacologic treatments not indicated by the FDA for the treatment of ADHD. Data for these interventions was limited to studies including 50 or more patients with ADHD, with no specific requirement for length of followup.

This change in scope was performed in consultation with the nominating partner and the TEP in order to focus the systematic review on the areas of the greatest uncertainty and potential impact.

Another limitation of this review is that medication doses were not abstracted. Abstracting specific doses is challenging because many of the studies are based on dose escalation and there is often insufficient information to be able to determine the dose per subject body weight.

## Research Recommendations

ADHD is a common health problem that can be associated with significant impairment over the life span. The current evidence base has several significant gaps regarding diagnosis, treatment, and follow-up in the primary care setting. We did not identify any ongoing studies through trial registries that would help resolve the gap. Here we describe opportunities for future research organized by the three KQs.

### KQ 1 ADHD Diagnosis Research Gaps

Significant gaps related to KQ 1 include the lack of studies conducted in primary care and the lack of studies that prospectively evaluate the harm of labeling.

- Validity and reliability of behavior scales in direct comparison to new strategies for diagnosis:
  ○ Studies should include a typical population of children and adolescents in primary care seeking initial diagnosis.
  ○ The tools should be performed in the primary care setting.
  ○ Confirmation should be based on DSM-5 criteria by an expert within a short period of time to evaluate in the primary care setting. The expert should be blinded to the results in primary care.
  ○ Receiver operator characteristic (ROC) curves should be generated to evaluate the validity of diagnosis using different cut-offs for the behavior scales and consider the impact of combining behavior scales with other diagnostic strategies.
  ○ Results should be stratified by age group and ADHD subtype.
  ○ Reliability (test-retest reliability, inter-observer reliability, and intra-observer reliability) should be evaluated.
- Harms of labeling: These can be assessed in a longitudinal cohort of patients diagnosed with ADHD as part of an overall study to evaluate the effectiveness of interventions (see KQ 2).

### KQ 2 ADHD Treatment Research Gaps

Significant gaps related to KQ 2 include the lack of studies conducted in primary care and the short duration of follow-up.

- Effectiveness of treatment:
  ○ Secondary data analysis of electronic record data could be used to assess outcomes from large cohorts of patients, but would be limited to the available data and lack of randomization.
  ○ Typical care would be better informed by a pragmatic randomized trial that includes the typical spectrum of patients seen in primary care. Pragmatic trials can be embedded with electronic medical records, making prospective studies more feasible.
  ○ Three-arm studies, using pharmacologic, nonpharmacologic treatments (e.g., behavioral interventions), and a combination of approaches are needed. In a pragmatic trial, therapy could be escalated or combined, based on the responsiveness to treatment.
  ○ Although behavioral interventions are recommended, more research is needed about the comparative effectiveness of different approaches and how behavioral interventions can be personalized within the context of care in which most children and adolescents are treated.
  ○ Studies should include a wide range of outcomes, including behavior rating scales, school functioning, risk-taking behaviors, growth and development, comorbid psychiatric disorders, and the typical adverse events monitored in drug trials.
  ○ Studies should have a meaningful duration. Ideally, those enrolled in a pragmatic trial would be followed for multiple years.
  ○ Studies should include the full spectrum of children and adolescents seeking care in the primary care setting.
  ○ Follow-up monitoring should be evaluated, as described for KQ 3.

### KQ 3 ADHD Monitoring Research Gaps

Monitoring individuals with ADHD is a central to assuring optimal treatment outcomes. It allows for modification of the treatment plan based on assessment of adherence, changes in symptoms, the presence of comorbidity, the effectiveness of therapy, and the presence of any treatment-related harms. Factors that should be considered are time intervals, setting (e.g., primary care vs. specialty care), and the type of information to be evaluated. In addition, the role of technology should be considered. For example, the use of technology (e.g., Web-based tools or smartphone applications) could allow the collection of a wide array of data and decrease the need for in-clinic evaluations. Telemedicine might enable health care providers to communicate with the patient, family, and teachers.

- Monitoring treatment:
  ○ Within a pragmatic trial, different strategies for monitoring could be embedded.
  ○ Strategies should include the use of technology versus traditional in-person evaluations.
  ○ The frequency of monitoring should be a function of the ADHD symptoms and the intervention.

## Conclusions

Additional benefit of new strategies for diagnosing ADHD (e.g., imaging, EEG) is unclear. Little is known about the harm of labeling. For ADHD treatment, the 2011 report found benefits for psychostimulant therapy and behavioral therapy. This report using more stringent criteria for inclusion (e.g., diagnostic confirmation of ADHD) found evidence for behavioral therapy improving ADHD symptoms but no difference in academic performance and insufficient evidence for other outcomes. In addition, we found that omega-3/6 fatty acid supplementation does not appear to be effective in reducing ADHD symptoms. Overall, this review highlights the need for more research regarding behavioral therapies. There are insufficient data available to determine whether variations exist in effectiveness by age, sex, or presenting ADHD symptoms. No data were identified to determine the optimal strategy for monitoring children and adolescents with ADHD.