# Appendix F Characteristics of Included Studies

Appendix Table F-1 Characteristics of included studies for KQ 1

Appendix Table F-2 Characteristics of included studies for KQ 2

## References to Appendix F

1 Berger I, Goldzweig G. Objective measures of attention-deficit/hyperactivity disorder: a pilot study. Isr Med Assoc J. 2010 Sep;12(9):531–5. PMID: 21287795.21287795
2 Bloch Y, Fixman M, Maoz H, . Can computerized cognitive tests assist in the clinical diagnosis of attention-deficit hyperactivity disorder? J Neuropsychiatry Clin Neurosci. 2012 Winter;24(1):111–4. doi: 10.1176/appi.neuropsych.11010014. PMID: 22450621.22450621
3 Bunte TL, Schoemaker K, Hessen DJ, . Clinical usefulness of the Kiddie-Disruptive Behavior Disorder Schedule in the diagnosis of DBD and ADHD in preschool children. J Abnorm Child Psychol. 2013 Jul;41(5):681–90. doi: 10.1007/s10802-013-9732-1. PMID: 23474833.23474833
4 Carballo JJ, Rodriguez-Blanco L, Garcia-Nieto R, . Screening for the ADHD Phenotype Using the Strengths and Difficulties Questionnaire in a Clinical Sample of Newly Referred Children and Adolescents. J Atten Disord. 2014 Dec 16doi: 10.1177/1087054714561858. PMID: 25515677.25515677
5 Castro-Cabrera P, Gomez-Garcia J, Restrepo F, . Evaluation of feature extraction techniques on event-related potentials for detection of attention-deficit/hyperactivity disorder. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:851–4. doi: 10.1109/iembs.2010.5626862. PMID: 21096317.21096317
6 Caudal F. New marker using bioimpedance technology in screening for attention deficit/hyperactivity disorder (ADHD) in children as an adjunct to conventional diagnostic methods. Psychol Res Behav Manag. 2011;4:113–7. doi: 10.2147/prbm.s22924. PMID: 22114541.22114541
7 dosReis S, Barksdale CL, Sherman A, . Stigmatizing experiences of parents of children with a new diagnosis of ADHD. Psychiatric Services. 2010;61(8):811–6. doi: 10.1176/appi.ps.61.8.811. PMID: 2010-16657-009.20675840
8 Ferrin M, Vance A. Examination of neurological subtle signs in ADHD as a clinical tool for the diagnosis and their relationship to spatial working memory. J Child Psychol Psychiatry. 2012 Apr;53(4):390–400. doi: 10.1111/j.1469-7610.2011.02496.x. PMID: 22141455.22141455
9 Gonzalez JJ, Mendez LD, Manas S, . Performance analysis of univariate and multivariate EEG measurements in the diagnosis of ADHD. Clin Neurophysiol. 2013 Jun;124(6):1139–50. doi: 10.1016/j.clinph.2012.12.006. PMID: 23332776.23332776
10 Kim JW, Lee J, Kim BN, . Theta-phase gamma-amplitude coupling as a neurophysiological marker of attention deficit/hyperactivity disorder in children. Neurosci Lett. 2015 Aug 31;603:25–30. doi: 10.1016/j.neulet.2015.07.006. PMID: 26170246.26170246
11 Kim J, Lee Y, Han D, . The utility of quantitative electroencephalography and Integrated Visual and Auditory Continuous Performance Test as auxiliary tools for the Attention Deficit Hyperactivity Disorder diagnosis. Clin Neurophysiol. 2015 Mar;126(3):532–40. doi: 10.1016/j.clinph.2014.06.034. PMID: 25088931.25088931
12 Klenberg L, Jamsa S, Hayrinen T, . The Attention and Executive Function Rating Inventory (ATTEX): Psychometric properties and clinical utility in diagnosing ADHD subtypes. Scand J Psychol. 2010 Mar 19;51(5):439–48. doi: 10.1111/j.1467-9450.2010.00812.x. PMID: 20338019.20338019
13 Liechti MD, Valko L, Muller UC, . Diagnostic value of resting electroencephalogram in attention-deficit/hyperactivity disorder across the lifespan. Brain Topogr. 2013 Jan;26(1):135–51. doi: 10.1007/s10548-012-0258-6. PMID: 23053601.23053601
14 Markovska-Simoska S, Pop-Jordanova N. Quantitative EEG in Children and Adults With Attention Deficit Hyperactivity Disorder: Comparison of Absolute and Relative Power Spectra and Theta/Beta Ratio. Clin EEG Neurosci. 2016 May 11doi: 10.1177/1550059416643824. PMID: 27170672.27170672
15 Martin-Martinez D, Casaseca-de-la-Higuera P, Alberola-Lopez S, . Nonlinear analysis of actigraphic signals for the assessment of the attention-deficit/hyperactivity disorder (ADHD). Med Eng Phys. 2012 Nov;34(9):1317–29. doi: 10.1016/j.medengphy.2011.12.023. PMID: 22297088.22297088
16 Ogrim G, Kropotov J, Hestad K. The quantitative EEG theta/beta ratio in attention deficit/hyperactivity disorder and normal controls: sensitivity, specificity, and behavioral correlates. Psychiatry Res. 2012 Aug 15;198(3):482–8. doi: 10.1016/j.psychres.2011.12.041. PMID: 22425468.22425468
17 Ohan JL, Visser TAW, Strain MC, . Teachers’ and education students’ perceptions of and reactions to children with and without the diagnostic label ‘ADHD’. Journal of School Psychology. 2011;49(1):81–105. doi: 10.1016/j.jsp.2010.10.001. PMID: 2011-00464-004.21215837
18 Park J, Kim C, Ahn JH, . Clinical Use of Continuous Performance Tests to Diagnose Children With ADHD. J Atten Disord. 2016 Jul 12doi: 10.1177/1087054716658125. PMID: 27412120.27412120
19 Soliva JC, Fauquet J, Bielsa A, . Quantitative MR analysis of caudate abnormalities in pediatric ADHD: proposal for a diagnostic test. Psychiatry Res. 2010 Jun 30;182(3):238–43. doi: 10.1016/j.pscychresns.2010.01.013. PMID: 20488672.20488672
20 Thorell LB, Eninger L, Brocki KC, . Childhood executive function inventory (CHEXI): a promising measure for identifying young children with ADHD? J Clin Exp Neuropsychol. 2010 Jan;32(1):38–43. doi: 10.1080/13803390902806527. PMID: 19381995.19381995
21 Zelnik N, Bennett-Back O, Miari W, . Is the test of variables of attention reliable for the diagnosis of attention-deficit hyperactivity disorder (ADHD)? J Child Neurol. 2012 Jun;27(6):703–7. doi: 10.1177/0883073811423821. PMID: 22378668.22378668
22 Abikoff H, Gallagher R, Wells KC, . Remediating organizational functioning in children with ADHD: immediate and long-term effects from a randomized controlled trial. J Consult Clin Psychol. 2013 Feb;81(1):113–28. doi: 10.1037/a0029648. PMID: 22889336.22889336
23 Abikoff HB, Thompson M, Laver-Bradbury C, . Parent training for preschool ADHD: a randomized controlled trial of specialized and generic programs. J Child Psychol Psychiatry. 2015 Jun;56(6):618–31. doi: 10.1111/jcpp.12346. PMID: 25318650.25318650
24 Anand P, Sachdeva A. Effect of Poly Unsaturated Fatty Acids Administration on Children with Attention Deficit Hyperactivity Disorder: A Randomized Controlled Trial. J Clin Diagn Res. 2016 Sep;10(9):Oc01–oc5. doi: 10.7860/jcdr/2016/20423.8471. PMID: 27790483.27790483
25 Arcieri R, Germinario EA, Bonati M, . Cardiovascular measures in children and adolescents with attention-deficit/hyperactivity disorder who are new users of methylphenidate and atomoxetine. J Child Adolesc Psychopharmacol. 2012 Dec;22(6):423–31. PMID: 23362511.23362511
26 Arnold LE, Disilvestro RA, Bozzolo D, . Zinc for attention-deficit/hyperactivity disorder: placebo-controlled double-blind pilot trial alone and combined with amphetamine. J Child Adolesc Psychopharmacol. 2011 Feb;21(1):1–19. doi: 10.1089/cap.2010.0073. PMID: 21309695.21309695
27 Bai GN, Wang YF, Yang L, . Effectiveness of a focused, brief psychoeducation program for parents of ADHD children: Improvement of medication adherence and symptoms. Neuropsychiatr Dis Treat. 2015;11:2721–35.26604761
28 Banaschewski T, Johnson M, Lecendreux M, . Health-related quality of life and functional outcomes from a randomized-withdrawal study of long-term lisdexamfetamine dimesylate treatment in children and adolescents with attention-deficit/hyperactivity disorder. CNS Drugs. 2014 Dec;28(12):1191–203. doi: 10.1007/s40263-014-0193-z. PMID: 25139785.25139785
29 Barragan E, Breuer D, Dopfner M. Efficacy and Safety of Omega-3/6 Fatty Acids, Methylphenidate, and a Combined Treatment in Children With ADHD. J Atten Disord. 2014 Jan 24doi: 10.1177/1087054713518239. PMID: 24464327.24464327
30 Beck SJ, Hanson CA, Puffenberger SS, . A controlled trial of working memory training for children and adolescents with ADHD. J Clin Child Adolesc Psychol. 2010;39(6):825–36. doi: 10.1080/15374416.2010.517162. PMID: 21058129.21058129
31 Bink M, van Nieuwenhuizen C, Popma A, . Behavioral effects of neurofeedback in adolescents with ADHD: a randomized controlled trial. Eur Child Adolesc Psychiatry. 2015 Sep;24(9):1035–48. doi: 10.1007/s00787-014-0655-3. PMID: 25477074.25477074
32 Boyer BE, Geurts HM, Prins PJ, . Two novel CBTs for adolescents with ADHD: the value of planning skills. Eur Child Adolesc Psychiatry. 2015 Sep;24(9):1075–90. doi: 10.1007/s00787-014-0661-5. PMID: 25549767.25549767
33 Çetin FH, Taş Torun Y, Işik Taner Y. Atomoxetine versus OROS methylphenidate in attention deficit hyperactivity disorder: A six-month follow up study for efficacy and adverse effects. Turkiye Klinikleri Journal of Medical Sciences. 2015;35(2):88–96.
34 Chacko A, Bedard AC, Marks DJ, . A randomized clinical trial of Cogmed Working Memory Training in school-age children with ADHD: a replication in a diverse sample using a control condition. J Child Psychol Psychiatry. 2014 Mar;55(3):247–55. doi: 10.1111/jcpp.12146. PMID: 24117656.24117656
35 Chacko A, Wymbs BT, Wymbs FA, . Enhancing traditional behavioral parent training for single mothers of children with ADHD. J Clin Child Adolesc Psychol. 2009 Mar;38(2):206–18. doi: 10.1080/15374410802698388. PMID: 19283599.19283599
36 Clemow DB, Mason OW, Sarkis EH, . Atomoxetine monotherapy compared with combination therapy for the treatment of ADHD: a retrospective chart review study. Expert Rev Neurother. 2015 Oct 21;15(11):1353–66. doi: 10.1586/14737175.2015.1102060. PMID: 26488905.26488905
37 Cortese S, Panei P, Arcieri R, . Safety of Methylphenidate and Atomoxetine in Children with Attention-Deficit/Hyperactivity Disorder (ADHD): Data from the Italian National ADHD Registry. CNS Drugs. 2015 Oct;29(10):865–77. doi: 10.1007/s40263-015-0266-7. PMID: 26293742.26293742
38 Didoni A, Sequi M, Panei P, . One-year prospective follow-up of pharmacological treatment in children with attention-deficit/hyperactivity disorder. Eur J Clin Pharmacol. 2011 Oct;67(10):1061–7. doi: 10.1007/s00228-011-1050-3. PMID: 21538145.21538145
39 Dovis S, Van der Oord S, Wiers RW, . Improving executive functioning in children with ADHD: training multiple executive functions within the context of a computer game. a randomized double-blind placebo controlled trial. PLoS One. 2015;10(4):e0121651. doi: 10.1371/journal.pone.0121651. PMID: 25844638.25844638
40 Duric NS, Assmus J, Gundersen D, . Neurofeedback for the treatment of children and adolescents with ADHD: a randomized and controlled clinical trial using parental reports. BMC Psychiatry. 2012;12:107. doi: 10.1186/1471-244x-12-107. PMID: 22877086.22877086
41 Dutta B, Barua TK, Ray J, . A study of evaluation of safety and efficacy of memomet, a multi herbal formulation (memomet) in the treatment of behavioural disorder in children. International Journal of Research in Pharmaceutical Sciences. 2012;3(2):282–6.
42 Egeland J, Aarlien AK, Saunes BK. Few effects of far transfer of working memory training in ADHD: a randomized controlled trial. PLoS One. 2013;8(10):e75660. doi: 10.1371/journal.pone.0075660. PMID: 24124503.24124503
43 Ercan ES, Ardic UA, Kutlu A, . No beneficial effects of adding parent training to methylphenidate treatment for ADHD + ODD/CD children: a 1-year prospective follow-up study. J Atten Disord. 2014 Feb;18(2):145–57. doi: 10.1177/1087054711432884. PMID: 22522574.22522574
44 Evans SW, Langberg JM, Schultz BK, . Evaluation of a School-Based Treatment Program for Young Adolescents With ADHD. Journal of Consulting and Clinical Psychology. 2016;84(1):15–30.26501496
45 Ferrin M, Moreno-Granados JM, Salcedo-Marin MD, . Evaluation of a psychoeducation programme for parents of children and adolescents with ADHD: immediate and long-term effects using a blind randomized controlled trial. Eur Child Adolesc Psychiatry. 2014 Aug;23(8):637–47. doi: 10.1007/s00787-013-0494-7. PMID: 24292412.24292412
46 Ferrin M, Perez-Ayala V, El-Abd S, . A Randomized Controlled Trial Evaluating the Efficacy of a Psychoeducation Program for Families of Children and Adolescents With ADHD in the United Kingdom: Results After a 6-Month Follow-Up. J Atten Disord. 2016 Feb 2doi: 10.1177/1087054715626509. PMID: 26838557.26838557
47 Findling RL, Adeyi B, Chen G, . Clinical response and symptomatic remission in children treated with lisdexamfetamine dimesylate for attention-deficit/hyperactivity disorder. CNS Spectrums. 2010;15(9):559–68.
48 Gelade K, Janssen TW, Bink M, . Behavioral Effects of Neurofeedback Compared to Stimulants and Physical Activity in Attention-Deficit/Hyperactivity Disorder: A Randomized Controlled Trial. J Clin Psychiatry. 2016 Oct;77(10):e1270–e7. doi: 10.4088/JCP.15m10149. PMID: 27631143.27631143
49 Gevensleben H, Holl B, Albrecht B, . Is neurofeedback an efficacious treatment for ADHD? A randomised controlled clinical trial. J Child Psychol Psychiatry. 2009 Jul;50(7):780–9. doi: 10.1111/j.1469-7610.2008.02033.x. PMID: 19207632.19207632
50 Gustafsson PA, Birberg-Thornberg U, Duchen K, . EPA supplementation improves teacher-rated behaviour and oppositional symptoms in children with ADHD. Acta Paediatr. 2010 Oct;99(10):1540–9. doi: 10.1111/j.1651-2227.2010.01871.x. PMID: 20491709.20491709
51 Hahn-Markowitz J, Berger I, Manor I, . Efficacy of Cognitive-Functional (Cog-Fun) Occupational Therapy Intervention Among Children With ADHD: An RCT. J Atten Disord. 2016 Sep 16doi: 10.1177/1087054716666955. PMID: 27637735.27637735
52 Hammerness P, Petty C, Faraone SV, . Do Stimulants Reduce the Risk for Alcohol and Substance Use in Youth With ADHD? A Secondary Analysis of a Prospective, 24-Month Open-Label Study of Osmotic-Release Methylphenidate. J Atten Disord. 2012 Dec 20doi: 10.1177/1087054712468051. PMID: 23264367.23264367
53 Hariri M, Djazayery A, Djalali M, . Effect of n-3 supplementation on hyperactivity, oxidative stress and inflammatory mediators in children with attention-deficit-hyperactivity disorder. Malays J Nutr. 2012 Dec;18(3):329–35. PMID: 24568073.24568073
54 Hiscock H, Sciberras E, Mensah F, . Impact of a behavioural sleep intervention on symptoms and sleep in children with attention deficit hyperactivity disorder, and parental mental health: randomised controlled trial. BMJ. 2015;350:h68. doi: 10.1136/bmj.h68. PMID: 25646809.25646809
55 Hong SS, Cho SH. Treating attention deficit hyperactivity disorder with acupuncture: A randomized controlled trial. European Journal of Integrative Medicine. 2015.
56 Huang YH, Chung CY, Ou HY, . Treatment effects of combining social skill training and parent training in Taiwanese children with attention deficit hyperactivity disorder. Journal of the Formosan Medical Association. 2015;114(3):260–7.25777975
57 Johnson M, Ostlund S, Fransson G, . Omega-3/omega-6 fatty acids for attention deficit hyperactivity disorder: a randomized placebo-controlled trial in children and adolescents. J Atten Disord. 2009 Mar;12(5):394–401. doi: 10.1177/1087054708316261. PMID: 18448859.18448859
58 Katz M, Levine AA, Kol-Degani H, . A compound herbal preparation (CHP) in the treatment of children with ADHD: a randomized controlled trial. J Atten Disord. 2010 Nov;14(3):281–91. doi: 10.1177/1087054709356388. PMID: 20228219.20228219
59 Li JJ, Li ZW, Wang SZ, . Ningdong granule: a complementary and alternative therapy in the treatment of attention deficit/hyperactivity disorder. Psychopharmacology (Berl). 2011 Aug;216(4):501–9. doi: 10.1007/s00213-011-2238-z. PMID: 21416235.21416235
60 Manor I, Magen A, Keidar D, . The effect of phosphatidylserine containing Omega3 fatty-acids on attention-deficit hyperactivity disorder symptoms in children: a double-blind placebo-controlled trial, followed by an open-label extension. Eur Psychiatry. 2012 Jul;27(5):335–42. doi: 10.1016/j.eurpsy.2011.05.004. PMID: 21807480.21807480
61 Mautone JA, Marshall SA, Sharman J, . Development of a Family-School Intervention for Young Children With Attention Deficit Hyperactivity Disorder. School Psych Rev. 2012;41(4):447–66. PMID: 24353368.24353368
62 Milte CM, Parletta N, Buckley JD, . Eicosapentaenoic and docosahexaenoic acids, cognition, and behavior in children with attention-deficit/hyperactivity disorder: a randomized controlled trial. Nutrition. 2012 Jun;28(6):670–7. doi: 10.1016/j.nut.2011.12.009. PMID: 22541055.22541055
63 Mohammadi MR, Mostafavi SA, Keshavarz SA, . Melatonin effects in methylphenidate treated children with attention deficit hyperactivity disorder: a randomized double blind clinical trial. Iran J Psychiatry. 2012 Spring;7(2):87–92. PMID: 22952551.22952551
64 Mohammadpour N, Jazayeri S, Tehrani-Doost M, . Effect of vitamin D supplementation as adjunctive therapy to methylphenidate on ADHD symptoms: A randomized, double blind, placebo-controlled trial. Nutr Neurosci. 2016 Dec 07:1–8. doi: 10.1080/1028415x.2016.1262097. PMID: 27924679.27924679
65 Molina BS, Hinshaw SP, Swanson JM, . The MTA at 8 years: prospective follow-up of children treated for combined-type ADHD in a multisite study. J Am Acad Child Adolesc Psychiatry. 2009 May;48(5):484–500. doi: 10.1097/CHI.0b013e31819c23d0. PMID: 19318991.19318991
66 Moreno-García I, Delgado-Pardoa G, de Reya CC-V, . Neurofeedback, pharmacological treatment and behavioral therapy in hyperactivity: Multilevel analysis of treatment effects on electroencephalography. International Journal of Clinical and Health Psychology. 2015;15(3):217–25. doi: 10.1016/j.ijchp.2015.04.003. PMID: 2015-48012-005.
67 Myers K, Vander Stoep A, Zhou C, . Effectiveness of a telehealth service delivery model for treating attention-deficit/hyperactivity disorder: a community-based randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2015 Apr;54(4):263–74. doi: 10.1016/j.jaac.2015.01.009. PMID: 25791143.25791143
68 Newcorn JH, Harpin V, Huss M, . Extended-release guanfacine hydrochloride in 6–17-year olds with ADHD: a randomised-withdrawal maintenance of efficacy study. J Child Psychol Psychiatry. 2016 Jun;57(6):717–28. doi: 10.1111/jcpp.12492. PMID: 26871297.26871297
69 Oberai P, Gopinadhan S, Varanasi R, . Homoeopathic management of attention deficit hyperactivity disorder: A randomised placebo-controlled pilot trial. Indian Journal of Research in Homeopathy. 2013;7(4):158–67.
70 Ostberg M, Rydell AM. An efficacy study of a combined parent and teacher management training programme for children with ADHD. Nord J Psychiatry. 2012 Apr;66(2):123–30. doi: 10.3109/08039488.2011.641587. PMID: 22150634.22150634
71 Panei P, Arcieri R, Bonati M, . Safety of psychotropic drug prescribed for attention-deficit/hyperactivity disorder in Italy. Adverse Drug Reaction Bulletin. 2010(260):999–1002.
72 Pelsser LM, Frankena K, Toorman J, . Effects of a restricted elimination diet on the behaviour of children with attention-deficit hyperactivity disorder (INCA study): a randomised controlled trial. Lancet. 2011 Feb 5;377(9764):494–503. doi: 10.1016/s0140-6736(10)62227-1. PMID: 21296237.21296237
73 Pfiffner LJ, Hinshaw SP, Owens E, . A two-site randomized clinical trial of integrated psychosocial treatment for ADHD-inattentive type. J Consult Clin Psychol. 2014 Dec;82(6):1115–27. doi: 10.1037/a0036887. PMID: 24865871.24865871
74 Power TJ, Mautone JA, Soffer SL, . A family-school intervention for children with ADHD: results of a randomized clinical trial. J Consult Clin Psychol. 2012 Aug;80(4):611–23. doi: 10.1037/a0028188. PMID: 22506793.22506793
75 Raz R, Carasso RL, Yehuda S. The influence of short-chain essential fatty acids on children with attention-deficit/hyperactivity disorder: a double-blind placebo-controlled study. J Child Adolesc Psychopharmacol. 2009 Apr;19(2):167–77. doi: 10.1089/cap.2008.070. PMID: 19364294.19364294
76 Salehi B, Imani R, Mohammadi MR, . Ginkgo biloba for attention-deficit/hyperactivity disorder in children and adolescents: a double blind, randomized controlled trial. Prog Neuropsychopharmacol Biol Psychiatry. 2010 Feb 1;34(1):76–80. doi: 10.1016/j.pnpbp.2009.09.026. PMID: 19815048.19815048
77 Sallee FR, Lyne A, Wigal T, . Long-term safety and efficacy of guanfacine extended release in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009 Jun;19(3):215–26. doi: 10.1089/cap.2008.0080. PMID: 19519256.19519256
78 Sayer GR, McGough JJ, Levitt J, . Acute and Long-Term Cardiovascular Effects of Stimulant, Guanfacine, and Combination Therapy for Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2016 Aug 2doi: 10.1089/cap.2015.0264. PMID: 27483130.27483130
79 Shakibaei F, Radmanesh M, Salari E, . Ginkgo biloba in the treatment of attention-deficit/hyperactivity disorder in children and adolescents. A randomized, placebo-controlled, trial. Complement Ther Clin Pract. 2015 May;21(2):61–7. doi: 10.1016/j.ctcp.2015.04.001. PMID: 25925875.25925875
80 Sibley MH, Graziano PA, Kuriyan AB, . Parent-teen behavior therapy + motivational interviewing for adolescents with ADHD. J Consult Clin Psychol. 2016 Aug;84(8):699–712. doi: 10.1037/ccp0000106. PMID: 27077693.27077693
81 Steiner NJ, Frenette EC, Rene KM, . Neurofeedback and cognitive attention training for children with attention-deficit hyperactivity disorder in schools. J Dev Behav Pediatr. 2014 Jan;35(1):18–27. doi: 10.1097/dbp.0000000000000009. PMID: 24399101.24399101
82 Storebo OJ, Gluud C, Winkel P, . Social-skills and parental training plus standard treatment versus standard treatment for children with ADHD--the randomised SOSTRA trial. PLoS One. 2012;7(6):e37280. doi: 10.1371/journal.pone.0037280. PMID: 22745657.22745657
83 Tobaiqy M, Stewart D, Helms PJ, . Parental reporting of adverse drug reactions associated with attention-deficit hyperactivity disorder (ADHD) medications in children attending specialist paediatric clinics in the UK. Drug Saf. 2011 Mar 1;34(3):211–9. doi: 10.2165/11586050-000000000-00000. PMID: 21332245.21332245
84 Trzepacz PT, Spencer TJ, Zhang S, . Effect of atomoxetine on Tanner stage sexual development in children and adolescents with attention deficit/hyperactivity disorder: 18-month results from a double-blind, placebo-controlled trial. Curr Med Res Opin. 2011;27 Suppl 2:45–52. doi: 10.1185/03007995.2011.599372. PMID: 21973230.21973230
85 van der Donk M, Hiemstra-Beernink AC, Tjeenk-Kalff A, . Cognitive training for children with ADHD: a randomized controlled trial of cogmed working memory training and ‘paying attention in class’. Front Psychol. 2015;6:1081. doi: 10.3389/fpsyg.2015.01081. PMID: 26284005.26284005
86 van Dongen-Boomsma M, Vollebregt MA, Buitelaar JK, . Working memory training in young children with ADHD: a randomized placebo-controlled trial. J Child Psychol Psychiatry. 2014 Aug;55(8):886–96. doi: 10.1111/jcpp.12218. PMID: 24628438.24628438
87 Vidal R, Castells J, Richarte V, . Group therapy for adolescents with attention-deficit/hyperactivity disorder: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2015 Apr;54(4):275–82. doi: 10.1016/j.jaac.2014.12.016. PMID: 25791144.25791144
88 Webster-Stratton CH, Reid MJ, Beauchaine T. Combining parent and child training for young children with ADHD. J Clin Child Adolesc Psychol. 2011;40(2):191–203. doi: 10.1080/15374416.2011.546044. PMID: 21391017.21391017
89 Widenhorn-Muller K, Schwanda S, Scholz E, . Effect of supplementation with long-chain omega-3 polyunsaturated fatty acids on behavior and cognition in children with attention deficit/hyperactivity disorder (ADHD): a randomized placebo-controlled intervention trial. Prostaglandins Leukot Essent Fatty Acids. 2014 Jul–Aug;91(1–2):49–60. doi: 10.1016/j.plefa.2014.04.004. PMID: 24958525.24958525
90 Zhang H, Du M, Zhuang S. Impact of long-term treatment of methylphenidate on height and weight of school age children with ADHD. Neuropediatrics. 2010 Aug;41(2):55–9. doi: 10.1055/s-0030-1261893. PMID: 20799150.20799150