# Appendix D List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reasons cited. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

### Not a Full Publication or Full Text Not Available

Ang A, Hillhouse M, Jenkins J, . Methylphenidate for methamphetamine use disorders in participants with and without ADHD. Drug and Alcohol Dependence. 2015;156:e7.
Bakhshayesh AR, Esser G and Wyschkon A. Effectiveness of EEG-biofeedback in the treatment of attention deficit/hyperactivity disorder. Psychological Research. 2010;13(1):7–29.
Bilder RM, Loo S, McGough JJ, . Cognitive effects of stimulant, guanfacine, and combined treatment in child and adolescent attention-deficit/hyperactivity disorder. Biological Psychiatry. 2016;79(9):158S.
Brittain S, Stocks J, Johnson J, . Adjunctive extended-release molindone (SPN-810) to manage impulsive aggression in children with attention deficit/hyperactivity disorder (ADHD) receiving optimized stimulant monotherapy and behavioral therapy. Neurology. 2016;86(16).
Carucci S, Caddeo M, Romaniello R, . Effects of methylphenidate on height in ADHD children. The monitoring of bone age within the ADDUCE project. European Neuropsychopharmacology. 2015;25:S644.
Coghill D, Hernández Otero I, Nagy P, . Long-term safety and efficacy of lisdexamfetamine dimesylate by age subgroup in children and adolescents with attention deficit hyperactivity disorder. Australian and New Zealand Journal of Psychiatry. 2016;50:162.
Coghill D, Nagy P, Frick G, . Comparing the time-course of efficacy of lisdexamfetamine dimesylate and osmotic controlled-release methylphenidate in children and adolescents with ADHD. Australian and New Zealand Journal of Psychiatry. 2016;50:114–115.
Coghill DR, Nagy P, Frick G, . Relative efficacy of lisdexamfetamine dimesylate and osmotic controlled-release methylphenidate in attention-deficit/hyperactivity disorder patients. European Neuropsychopharmacology. 2015;25:S647–S648.
Cutler A, Harper L, Young J, . Guanfacine extended release: Daytime sleepiness outcomes from a phase 3 clinical study in adolescents with attention-deficit/hyperactivity disorder. European Neuropsychopharmacology. 2015;25:S648–S649.
Emmerson NA. Monitoring patterns of physical activity, problematic behaviors, and moods in children with and without ADHD using electronic diaries. US: ProQuest Information & Learning; 2011.
FDA-approved drugs to treat ADHD. J Psychosoc Nurs Ment Health Serv. 2012;50(3):11–2. PMID: 22390784.22390784
Furnell C and Finlay F. The use of weighted blankets to modify sleep in attention deficit hyperactivity disorder (ADHD). Archives of Disease in Childhood. 2016;101:A354.
Gonring KA. Program for the education and enrichment of relational skills: Parental outcomes with an ADHD sample. 2016.
Hall CL, Walker GM and Valentine AZ. Correction. Protocol investigating the clinical utility of an objective measure of activity and attention (QbTest) on diagnostic and treatment decision-making in children and young people with ADHD - ‘Assessing QbTest Utility in ADHD’ (AQUA): a randomised controlled trial. BMJ Open. 2015;5(5):e006838corr1. PMID: 25948406.25948406
Hauser ME. Prediction of stimulant response in patients with adhd utilizing acute medication challenge studies. US: ProQuest Information & Learning; 2014.
Heishman A. Effectiveness of computerized working memory training on math achievement and other transfer effects in children with ADHD and math difficulties. 2016.
Helwig JR. Sleep disturbance in children and adolescents with adhd: Unique effects of medication, adhd subtype, and comorbid status. US: ProQuest Information & Learning; 2012.
Henriksen N. Impulsive choice in unmedicated and medicated children diagnosed with adhd: Examining the variables of reward type and adhd subtype. US: ProQuest Information & Learning; 2015.
Herbert SD. Parent training for families of hyperactive preschool-aged children. US: ProQuest Information & Learning; 2014.
Ishii-Takahashi A, Takizawa R, Nishimura Y, . Neuroimaging-Aided Prediction of the Effect of Methylphenidate in Children with Attention-Deficit Hyperactivity Disorder: A Randomized Controlled Trial. Neuropsychopharmacology. 2015;40(12):2852. PMID: 26152808.26152808
La Marca JP. Neurofeedback as an intervention to improve reading achievement in students with attention deficit hyperactivity disorder, inattentive subtype. US: ProQuest Information & Learning; 2015.
Lastra N. Predictors of response in the Multimodal Treatment of Attention Deficit and Hyperactivity Disorder trial. 2016.
Linden S. Risk of suicide and suicide attempt associated with atomoxetine compared to central nervous system stimulant treatment. 2016.
Moodi M, Alizadeh H, Bonab BG, . Effectiveness of cognitive behavior therapy on anger management in children with attention deficit/hyperactivity disorder. Psychological Research. 2015;17(2):112–127.
Moore SA. Impact of two-session model of child parent relationship training on parents of children diagnosed with ADHD. 2016.
Music A. Direct Behavior Ratings (DBR): A possible tool for monitoring the behavior and interventions of students with symptoms of Attention Deficit Hyperactivity Disorder (ADHD). US: ProQuest Information & Learning; 2012.
Nazer M. The effect of exercise therapy on symptoms of hyperactivity/attention deficit disorder in elementary school students in Rafsanjan. European Psychiatry. 2016;33(Supplement):S439.
Nupdal JB. Implementing clinical practice guidelines in family practice: Caring for children with ADHD. US: ProQuest Information & Learning; 2015.
Peksel H, Upadhyaya H, Adams DH, . Maintenance of effect in Attention Deficit Hyperactivity Disorder: What do placebo-controlled randomized withdrawal studies of atomoxetine and stimulants tell us?. Klinik Psikofarmakoloji Bulteni. 2015;25:S82.
Poh XW, Fung DSS, Lee TS, . Effectiveness of brain-computer interface-based programme boosters for the treatment of attention deficit hyperactivity in children-a preliminary analysis. Annals of the Academy of Medicine Singapore. 2015;44(10):S407.
Reading R. ADHD drugs and serious cardiovascular events in children and young adults. Child: Care, Health and Development. 2012;38(1):149–151.
Roberts AM. Randomized control study of neurofeedback with college students with ADHD. 2016.
Robinson AM. The effects of child-centered play therapy on the behavioral performance of elementary school students with ADHD. 2016.
Rostain AL. Guanfacine extended release in the treatment of attention-deficit/hyperactivity disorder. Curr Psychiatry Rep. 2009;11(5):339–40. PMID: 19785972.19785972
Russell EL. Auditory and visual sustained attention on tasks with varied motivation and cognitive loads in children with and without ADHD. 2016.
Rutledge KJ. Review and comparative effectiveness of parent training and cognitive training for treating attention-deficit/hyperactivity disorder. US: ProQuest Information & Learning; 2014.
Rynczak D. Effectiveness of mindfulness in reducing impulsivity in youth with attention-deficit/hyperactivity disorder. US: ProQuest Information & Learning; 2013.
Saheban F, Amiri S, Kajbaf MB, . The efficacy of short-term executive functions training on the reduction of symptoms of attention deficit and hyperactivity of elementary boy students in Esfahan metropolitan area. Advances in Cognitive Science. 2010;12(1):52–58.
Sanal Y, Yokusoglu C and Yargic I. Compliance with methylphenidate treatment and drug abuse of adults with attention deficit hyperactivity disorder (ADHD). Klinik Psikofarmakoloji Bulteni. 2015;25:S34–S36.
Shecter C. Mindfulness training for adolescents with ADHD and their families: A time-series evaluation. US: ProQuest Information & Learning; 2015.
Shemmassian SK. Optimizing assessment procedures for attention-deficit/hyperactivity disorder (adhd). US: ProQuest Information & Learning; 2015.
Sibley MH. Supporting Teens’ Academic Needs Daily (STAND): A parent-adolescent collaborative intervention for ADHD. US: ProQuest Information & Learning; 2013.
Sidhu P. The efficacy of mindfulness meditation in increasing the attention span in children with ADHD. US: ProQuest Information & Learning; 2015.
Sobanski E, Dopfner M, Ose C, . A non-interventional study of extended-release methylphenidate in the routine treatment of adolescents with ADHD: effectiveness, safety and adherence to treatment. Atten Defic Hyperact Disord. 2013;5(4):387–95. PMID: 23794192.23794192
Sohn M. The off-label use of atypical antipsychotics and its impact on Attention Deficit/Hyperactivity Disorder (ADHD). US: ProQuest Information & Learning; 2015.
Steeger CM. Combined cognitive and parent training interventions for adolescents with adhd and their mothers: A randomized, controlled trial. US: ProQuest Information & Learning; 2014.
Storebø OJ, Simonsen E and Gluud C. The evidence base of methylphenidate for children and adolescents with attention-deficit hyperactivity disorder is in fact flawed. European Child and Adolescent Psychiatry. 2016:1–2.26696307
Sura S, Chatterjee S, Kamble P, . Persistence of stimulants in children and adolescents with attention deficit hyperactivity disorder: A longitudinal study. Pharmacoepidemiology and Drug Safety. 2015;24:501–502.
Tomoda A, Takiguchi S, Fujisawa TX, . Effectiveness of oral tipepidine administration for children with attention deficit/hyperactivity disorder: A 4-week, open-label clinical study. Psychiatry and Clinical Neurosciences. 2015;69(10):658–659.
Treumer TN. Adult ADHD Self-Report Scale: Implementation in a primary care setting. 2016.
van Dongen-Boomsma M, Vollebregt MA, Slaats-Wlllemse D, . ‘A randomized placebo-controlled trial of electroencephalographic (EEG) neurofeedback in children with attention-deficit/hyperactivity disorder’: Reply. Journal of Clinical Psychiatry. 2014;75(3):290–290.24717384
Wagner SM. The effects of parent-child interaction therapy on symptoms and impairment in young children with attention-deficit/hyperactivity disorder. US: ProQuest Information & Learning; 2012.
Walker P, Jr. The effects of Ritalin and cognitive behavioral therapy on the academic functioning of African American children diagnosed with attention deficit hyperactivity disorder: A longitudinal study. US: ProQuest Information & Learning; 2011.
Worth DE. Mindfulness meditation and attention-deficit/hyperactivity disorder symptom reduction in middle school students. US: ProQuest Information & Learning; 2014.
Zuddas A, Banaschewski T, Nagy P, . Long-term safety and efficacy of lisdexamfetamine dimesylate in children and adolescents with attention-deficit/hyperactivity disorder. European Neuropsychopharmacology. 2015;25:S648.

### Not Available in English

Babaki ME, Ashtiani RD, Razjooyan K, . Comparing the effects of buspirone and methylphenidate in children with attention deficit hyperactivity disorder. Iranian Journal of Psychiatry and Clinical Psychology. 2009;15(3):223–230.
Blasco-Fontecilla H, Gonzalez-Perez M, Garcia-Lopez R, . Efficacy of chess training for the treatment of ADHD: A prospective, open label study. Rev Psiquiatr Salud Ment. 2015. PMID: 25911280.25911280
Davari-Ashtiani R, Jazayeri F, Arabgol F, . Psychometric properties of Persian version of Conners’ Adult Attention Deficit/Hyperactivity Disorder Rating Scale (screening form-self reporting). Iranian Journal of Psychiatry and Clinical Psychology. 2014;20(3):243–251.
De Giacomo A, De Giambattista C, Balducci R, . SCQ as a tool for screening ASD comorbidities with ADHD. Rivista di Psichiatria. 2015;50(1):34–37.25805353
Delgado-Mejía ID, Palencia-Avendaño ML, Mogollón-Rincón C, . Theta/beta ratio (NEBA) in the diagnosis of attention deficit hyperactivity disorder. Revista de Neurologia. 2014;58(SUPPL. 1):S57–S63.25252669
Díaz-Orueta U, Fernández-Fernández MA, Morillo-Rojas MD, . Efficacy of lisdexamphetamine to improve the behavioural and cognitive symptoms of attention deficit hyperactivity disorder: Treatment monitored by means of the aula nesplora virtual reality test. Revista de Neurologia. 2016;63(1):19–27.27345276
Fazeli Z, Shirazi E, Farid AA, . Effectiveness of medication and combined medication and parent management training on visuo-constructive, attentional, behavioral and emotional indicators of children with attention deficit/hyperactivity disorder. Iranian Journal of Psychiatry and Clinical Psychology. 2014;19(4):264–274.
Gandía-Benetó R, Mulas F, Roca P, . Change in the therapeutic strategy when faced with an inadequate response to the pharmacological treatment of attention deficit hyperactivity disorder. Revista de Neurologia. 2015;60:S8–S13.
Garcia Ron A, Serrano Grasa R, Blanco Lago R, . Pilot study of the efficacy of empowering patients through coaching as a complementary therapy in attention deficit hyperactivity disorder. Neurologia. 2015. PMID: 26383058.26383058
Ghasabi S, Tajrishi MPMR and Zamani SMM. The effect of verbal self-instruction training on decreasing impulsivity symptoms in ADHD children. Journal of Iranian Psychologists. 2009;5(19):209–220.
Jalali N, Shahrbabaki ME and Sahebozamani M. The effect of exercise program in reducing symptoms of attention deficit/hyperactivity disorder in children. Iranian Journal of Psychiatry and Clinical Psychology. 2015;20(4):309–316.
Karakurt MN, Karabekiroǧlu MK, Akbaş S, . Association between symptom profiles and iron and ferritine serum levels in children with attention deficit hyperactivity disorder. Noropsikiyatri Arsivi. 2011;48(2):125–128.
Khanjani Z, Amini S, Malek A, . The effectiveness of parents management training on improvement of attention deficit hyperactivity disorder syndrome in children. Journal of Iranian Psychologists. 2014;10(39):311–320.
Lazaratou H. Attention-deficit hyperactivity disorder or bipolar disorder in childhood?. Psychiatriki. 2012;23(4):304–313.23399752
Maleki ZH, Mashhadi A, Soltanifar A, . Effectiveness of working memory training, Barkley’s parent training program, and combination of these two interventions on improvement of working memory in children with ADHD. Advances in Cognitive Science. 2014;15(4[60]):53–63.
Meftagh SD, Mohammadi N, Ghanizadeh A, . Comparison of the effectiveness of different treatment methods in children’s attention deficit-hyperactivity disorders. Journal of Isfahan Medical School. 2011;29(148):965–976.
Morichi S, Miyajima T, Yamanaka G, . Effect of ATX and OROS-MPH alone or in combination on QT prolongation in ADHD patients. Journal of Tokyo Medical University. 2015;73(3):284–293.
Mulas F, Roca P, Ros-Cervera G, . Pharmacological management of attention deficit hyperactivity disorder with methylphenidate and atomoxetine within a context of epilepsy. Revista de Neurologia. 2014;58(SUPPL. 1):S43–S49.25252667
Shahrbabaki ME, Sabzevari L, Haghdoost A, . A randomized double blind crossover study on the effectiveness of buspirone and methylphenidate in treatment of attention deficit/hyperactivity disorder in children and adolescents. Iranian Journal of Psychiatry and Clinical Psychology. 2013;18(4):292–297.
Yu X, Liu L, Sun L, . Multi-dimensional exploration of the characteristics of emotional regulation in children with attention-deficit/hyperactivity disorder. National Medical Journal of China. 2015;95(39):3184–3189.26814115
Zamora J, Velasquez A, Troncoso L, . [Zinc in the therapy of the attention-deficit/hyperactivity disorder in children. A preliminar randomized controlled trial]. Arch Latinoam Nutr. 2011;61(3):242–6. PMID: 22696891.22696891

### Does Not Include Original Data

Barbaresi WJ, Katusic SK, Colligan RC, . Long-term stimulant medication treatment of attention-deficit/hyperactivity disorder: results from a population-based study. J Dev Behav Pediatr. 2014;35(7):448–57. PMID: 25180895.25180895
Bikic A, Leckman JF, Lindschou J, . Cognitive computer training in children with attention deficit hyperactivity disorder (ADHD) versus no intervention: study protocol for a randomized controlled trial. Trials. 2015;16(1):480. PMID: 26499057.26499057
Boyes C. Question 2 Should a child with ADHD and epilepsy be given ritalin?. Arch Dis Child. 2010;95(9):759–61. PMID: 20716679.20716679
Childress AC. Guanfacine extended release as adjunctive therapy to psychostimulants in children and adolescents with attention-deficit/hyperactivity disorder. Adv Ther. 2012;29(5):385–400. PMID: 22610723.22610723
Cole E. Qb test improves diagnosis of attention deficit disorder. Nurs Child Young People. 2015;27(2):10–1. PMID: 25759995.25759995
Cowles BJ. Update on the management of attention-deficit/hyperactivity disorder in children and adults: Patient considerations and the role of lisdexamfetamine. Therapeutics and Clinical Risk Management. 2009;5(1):943–948.20057893
Croxtall JD. Clonidine extended-release: in attention-deficit hyperactivity disorder. Paediatr Drugs. 2011;13(5):329–36. PMID: 21888447.21888447
Frances A. Better safe than sorry. Australian and New Zealand Journal of Psychiatry. 2012;46(8):695–696.22848053
Hansen S. Kids Together: A group therapy program for children using cognitive-behavioral play therapy interventions. In: Drewes AA, Schaefer CE, Drewes AA, Schaefer CE, eds. Play therapy in middle childhood. Washington, DC, US: American Psychological Association; 2016:153–69.
Hechtman L. Effects of treatment on the overall functioning of children with ADHD. Journal of the Canadian Academy of Child and Adolescent Psychiatry/Journal de l’Académie canadienne de psychiatrie de l’enfant et de l’adolescent. 2009;18(2,Suppl):11–16.
Hennessy S, Schelleman H, Daniel GW, . Cardiovascular safety of ADHD medications: rationale for and design of an investigator-initiated observational study. Pharmacoepidemiol Drug Saf. 2010;19(9):934–41. PMID: 20623519.20623519
Hinshaw SP and Arnold LE. ADHD, Multimodal Treatment, and Longitudinal Outcome: Evidence, Paradox, and Challenge. Wiley Interdiscip Rev Cogn Sci. 2015;6(1):39–52. PMID: 25558298.25558298
Huang YS, Tsai MH and Guilleminault C. Pharmacological treatment of ADHD and the short and long term effects on sleep. Curr Pharm Des. 2011;17(15):1450–8. PMID: 21476954.21476954
Hvolby A and Bilenberg N. Use of Ball Blanket in attention-deficit/hyperactivity disorder sleeping problems. Nord J Psychiatry. 2011;65(2):89–94. PMID: 20662681.20662681
Johnson M. The lure of an ADHD treatment minus the meds. US News World Rep. 2009;146(11):80–1. PMID: 20027829.20027829
Kean JD, Camfield D, Sarris J, . A randomized controlled trial investigating the effects of PCSO-524, a patented oil extract of the New Zealand green lipped mussel (Perna canaliculus), on the behaviour, mood, cognition and neurophysiology of children and adolescents (aged 6–14 years) experiencing clinical and sub-clinical levels of hyperactivity and inattention: study protocol ACTRN12610000978066. Nutr J. 2013;12:100. PMID: 23866813.23866813
Keating GM. Methylphenidate transdermal system in attention-deficit hyperactivity disorder in adolescents: profile report. Drugs R D. 2012;12(3):171–3. PMID: 22934753.22934753
Keating GM. Methylphenidate transdermal system: in attention-deficit hyperactivity disorder in adolescents. CNS Drugs. 2011;25(4):333–42. PMID: 21425884.21425884
Kerson C. A proposed multisite double-blind randomized clinical trial of neurofeedback for ADHD: need, rationale, and strategy. J Atten Disord. 2013;17(5):420–36. PMID: 23590978.23590978
Kieling R and Rohde LA. ADHD in children and adults: diagnosis and prognosis. Curr Top Behav Neurosci. 2012;9:1–16. PMID: 21499858.21499858
Kohn MR, Tsang TW and Clarke SD. Efficacy and safety of atomoxetine in the treatment of children and adolescents with attention deficit hyperactivity disorder. Clin Med Insights Pediatr. 2012;6:95–162. PMID: 23641171.23641171
Leben N. Directive group play therapy for children with attention-deficit/hyperactivity disorder. In: Kaduson HG, Schaefer CE, Kaduson HG, Schaefer CE, eds. Short-term play therapy for children (3rd ed.). New York, NY, US: Guilford Press; 2015:325–52.
McCann DC, Thompson M, Daley D, . Study protocol for a randomized controlled trial comparing the efficacy of a specialist and a generic parenting programme for the treatment of preschool ADHD. Trials. 2014;15:142. PMID: 24767423.24767423
Meppelink R, de Bruin EI and Bogels SM. Meditation or Medication? Mindfulness training versus medication in the treatment of childhood ADHD: a randomized controlled trial. BMC Psychiatry. 2016;16:267. PMID: 27460004.27460004
Methylphenidate: growth retardation. Prescrire Int. 2011;20(120):238–9. PMID: 21970086.21970086
Muir VJ and Perry CM. Guanfacine extended-release: in attention deficit hyperactivity disorder. Drugs. 2010;70(13):1693–702. PMID: 20731476.20731476
Ondrejka I, Abali O, Paclt I, . A prospective observational study of attention-deficit/hyperactivity disorder in Central and Eastern Europe and Turkey: Symptom severity and treatment options in a paediatric population. Int J Psychiatry Clin Pract. 2010;14(2):116–26. PMID: 24922471.24922471
Parens E and Johnston J. Troubled children: diagnosing, treating, and attending to context. A Hastings Center special report. Hastings Cent Rep. 2011;41(2):S1–32. PMID: 21495513.21495513
Pataki C and Carlson GA. The comorbidity of ADHD and bipolar disorder: any less confusion?. Curr Psychiatry Rep. 2013;15(7):372. PMID: 23712723.23712723
Pelsser LM, Steijn DJ and Frankena K. ‘A randomized controlled pilot study into the effects of a restricted elimination diet on family structure in families with ADHD and ODD’: Comment. Journal of Developmental and Behavioral Pediatrics. 2013;34(9):734–734.
Peyre H, Hoertel N, Cortese S, . Long-term effects of ADHD medication on adult height: Results from the NESARC. Journal of Clinical Psychiatry. 2013;74(11):1123–1125.
Pulgaron ER. Childhood obesity: a review of increased risk for physical and psychological comorbidities. Clin Ther. 2013;35(1):A18–32. PMID: 23328273.23328273
Reddy LA. Child ADHD multimodal program: Use of cognitive-behavioral group play interventions. In: Reddy LA, Files-Hall TM, Schaefer CE, Reddy LA, Files-Hall TM, Schaefer CE, eds. Empirically based play interventions for children (2nd ed.). Washington, DC, US: American Psychological Association; 2016:181–201.
Ross SM. Omega-3 fatty acids, part I: the effects of n-3 polyunsaturated fatty acid in the treatment of attention-deficit hyperactivity disorder in children. Holist Nurs Pract. 2012;26(6):356–9. PMID: 23075752.23075752
Sciberras E, Efron D, Gerner B, . Study protocol: the sleeping sound with attention-deficit/hyperactivity disorder project. BMC Pediatr. 2010;10:101. PMID: 21192797.21192797
Srinivasaraghavan R, Kattimani S and Mahadevan S. Duration of untreated illness and early treatment response in children with attention deficit/hyperactivity disorder—A preliminary study. Asian Journal of Psychiatry. 2014;9:87–88.24813044
Storebo OJ, Pedersen J, Skoog M, . Randomised social-skills training and parental training plus standard treatment versus standard treatment of children with attention deficit hyperactivity disorder - the SOSTRA trial protocol. Trials. 2011;12:18. PMID: 21255399.21255399
Study shows no link between stimulant use in ADHD treatment and cardiovascular events. Expert Review of Neurotherapeutics. 2012;12(4):369–369.
Swanson JM, Schuck S, Porter MM, . Categorical and dimensional definitions and evaluations of symptoms of ADHD: History of the SNAP and the SWAN rating scales. The International Journal of Educational and Psychological Assessment. 2012;10(1):51–70.26504617
Vaughan BS, March JS and Kratochvil CJ. The evidence-based pharmacological treatment of paediatric ADHD. Int J Neuropsychopharmacol. 2012;15(1):27–39. PMID: 21329553.21329553
Waxmonsky JG, Waschbusch DA, Glatt SJ, . Prediction of placebo response in 2 clinical trials of lisdexamfetamine dimesylate for the treatment of ADHD. J Clin Psychiatry. 2011;72(10):1366–75. PMID: 21367347.21367347
Weder N. Here/in this issue and there/abstract thinking: Are we there yet? Electroencephalography as a diagnostic tool for attention-deficit/hyperactivity disorder. Journal of the American Academy of Child & Adolescent Psychiatry. 2013;52(11):1119–1120.24157383
Zwi M, Jones H, Thorgaard C, . Parent training interventions for attention deficit hyperactivity disorder. Cochrane Database Syst Rev. 2009;(3). PMID: 25419178.25419178

### Does Not Meet Study Design or Sample Size Requirements

Aagaard L, Thirstrup S and Hansen EH. Opening the white boxes: the licensing documentation of efficacy and safety of psychotropic medicines for children. Pharmacoepidemiol Drug Saf. 2009;18(5):401–11. PMID: 19326364.19326364
Abbasi SH, Heidari S, Mohammadi MR, . Acetyl-L-carnitine as an adjunctive therapy in the treatment of attention-deficit/hyperactivity disorder in children and adolescents: a placebo-controlled trial. Child Psychiatry Hum Dev. 2011;42(3):367–75. PMID: 21336630.21336630
Abdollahian E, Mokhber N, Balaghi A, . The effectiveness of cognitive-behavioural play therapy on the symptoms of attention-deficit/hyperactivity disorder in children aged 7–9 years. Atten Defic Hyperact Disord. 2013;5(1):41–6. PMID: 23179507.23179507
Abibullaev B and An J. Decision support algorithm for diagnosis of ADHD using electroencephalograms. J Med Syst. 2012;36(4):2675–88. PMID: 21671069.21671069
Accorsi A, Lucci C, Di Mattia L, . Effect of osteopathic manipulative therapy in the attentive performance of children with attention-deficit/hyperactivity disorder. J Am Osteopath Assoc. 2014;114(5):374–81. PMID: 24778002.24778002
Adler LA, Wilens T, Zhang S, . Atomoxetine treatment outcomes in adolescents and young adults with attention-deficit/hyperactivity disorder: results from a post hoc, pooled analysis. Clin Ther. 2012;34(2):363–73. PMID: 22285724.22285724
Aebi M, Winkler Metzke C and Steinhausen HC. Accuracy of the DSM-oriented attention problem scale of the child behavior checklist in diagnosing attention-deficit hyperactivity disorder. J Atten Disord. 2010;13(5):454–63. PMID: 19372495.19372495
Ahmed R, Raynor DK, McCaffery KJ, . The design and user-testing of a question prompt list for attention-deficit/hyperactivity disorder. BMJ Open. 2014;4(12):e006585. PMID: 25515843.25515843
Albertin SV. Diagnosis of attention deficit hyperactivity disorder using a conditioned reflex approach. Neuroscience and Behavioral Physiology. 2011;41(9):906–910.
Albrecht B, Brandeis D, Uebel H, . Action monitoring in children with or without a family history of ADHD--effects of gender on an endophenotype parameter. Neuropsychologia. 2010;48(4):1171–7. PMID: 20026087.20026087
Alda JA and Serrano-Troncoso E. Attention-deficit hyperactivity disorder: agreement between clinical impression and the SNAP-IV screening tool. Actas Esp Psiquiatr. 2013;41(2):76–83. PMID: 23592067.23592067
Allen R and Pammer K. The Impact of Concurrent Noise on Visual Search in Children With ADHD. J Atten Disord. 2015. PMID: 26396146.26396146
Altin M, El-Shafei AA, Yu M, . Pharmacological treatment for attention deficit hyperactivity disorder: functional outcomes in children and adolescents from non-Western countries. Drugs Context. 2013;2013:212260. PMID: 24432046.24432046
Amado L, Jarque S and Ceccato R. Differential impact of a multimodal versus pharmacological therapy on the core symptoms of attention deficit/hyperactivity disorder in childhood. Research in Developmental Disabilities. 2016;59:93–104.27521718
Amiri S, AbdollahiFakhim S, Lotfi A, . Effect of adenotonsillectomy on ADHD symptoms of children with adenotonsillar hypertrophy and sleep disordered breathing. Int J Pediatr Otorhinolaryngol. 2015;79(8):1213–7. PMID: 26066853.26066853
Arabgol F, Panaghi L and Hebrani P. Reboxetine versus methylphenidate in treatment of children and adolescents with attention deficit-hyperactivity disorder. Eur Child Adolesc Psychiatry. 2009;18(1):53–9. PMID: 18563471.18563471
Arabgol F, Panaghi L and Nikzad V. Risperidone Versus Methylphenidate in Treatment of Preschool Children With Attention-Deficit Hyperactivity Disorder. Iran J Pediatr. 2015;25(1):e265. PMID: 26199694.26199694
Ardic UA, Ercan ES, Ercan E, . Osmotic release oral system methylphenidate is more effective than immediate release methylphenidate: A retrospective chart review in turkish children with attention deficit hyperactivity disorder. Klinik Psikofarmakoloji Bulteni. 2014;24(4):342–349.
Ari ME, Cetin II, Ekici F, . Assessment of cardiovascular risks due to methylphenidate in six months of treatment in children with attention deficit and hyperactivity disorder. Klinik Psikofarmakoloji Bulteni. 2014;24(3):248–252.
Armstrong RB, Damaraju CV, Ascher S, . Time course of treatment effect of OROS(R) methylphenidate in children with ADHD. J Atten Disord. 2012;16(8):697–705. PMID: 22084448.22084448
Arnold LE, Ganocy SJ, Mount K, . Three-year latent class trajectories of attention-deficit/hyperactivity disorder (ADHD) symptoms in a clinical sample not selected for ADHD. J Am Acad Child Adolesc Psychiatry. 2014;53(7):745–60. PMID: 24954824.24954824
Arnold LE, Hurt E and Lofthouse N. Attention-deficit/hyperactivity disorder: dietary and nutritional treatments. Child Adolesc Psychiatr Clin N Am. 2013;22(3):381–402, v. PMID: 23806311.23806311
Arnold LE, Lofthouse N, Hersch S, . EEG neurofeedback for ADHD: double-blind sham-controlled randomized pilot feasibility trial. J Atten Disord. 2013;17(5):410–9. PMID: 22617866.22617866
Ashare RL, Hawk LW, Jr., Shiels K, . Methylphenidate enhances prepulse inhibition during processing of task-relevant stimuli in attention-deficit/hyperactivity disorder. Psychophysiology. 2010;47(5):838–45. PMID: 20233343.20233343
Ashkenasi A. Effect of transdermal methylphenidate wear times on sleep in children with attention deficit hyperactivity disorder. Pediatr Neurol. 2011;45(6):381–6. PMID: 22115000.22115000
Assareh M, Davari Ashtiani R, Khademi M, . Efficacy of Polyunsaturated Fatty Acids (PUFA) in the Treatment of Attention Deficit Hyperactivity Disorder: A Randomized, Double-Blind, Placebo-Controlled Clinical Trial. J Atten Disord. 2012. PMID: 23160488.23160488
Au A, Lau KM, Wong AHC, . The efficacy of a group Triple P (positive parenting program) for Chinese parents with a child diagnosed with ADHD in Hong Kong: A pilot randomised controlled study. Australian Psychologist. 2014;49(3):151–162.
Azami S, Moghadas A, Sohrabi-Esmrood F, . A pilot randomized controlled trial comparing computer-assisted cognitive rehabilitation, stimulant medication, and an active control in the treatment of ADHD. Child and Adolescent Mental Health. 2016;21(4):217–224.
Azami S, Moghadas A, Sohrabi-Esmrood F, . Innovations in Practice: A pilot randomized controlled trial comparing computer-assisted cognitive rehabilitation, stimulant medication, and an active control in the treatment of ADHD. Child and Adolescent Mental Health. 2016.
Babinski DE, Waxmonsky JG and Pelham WE, Jr.. Treating parents with attention-deficit/hyperactivity disorder: the effects of behavioral parent training and acute stimulant medication treatment on parent-child interactions. J Abnorm Child Psychol. 2014;42(7):1129–40. PMID: 24687848.24687848
Babinski DE. Treating parents with attention-deficit/hyperactivity disorder: The effects of behavioral parent training and acute medication treatment on parent-child interactions. US: ProQuest Information & Learning; 2014.
Bakar EE, Taner YI, Soysal AS, . Behavioral rating inventory and laboratory tests measure different aspects of executive functioning in boys: A validity study. Klinik Psikofarmakoloji Bulteni. 2011;21(4):302–316.
Bakhshayesh AR, Hansch S, Wyschkon A, . Neurofeedback in ADHD: a single-blind randomized controlled trial. Eur Child Adolesc Psychiatry. 2011;20(9):481–91. PMID: 21842168.21842168
Ballard W, Hall MN and Kaufmann L. Clinical inquiries. Do dietary interventions improve ADHD symptoms in children?. J Fam Pract. 2010;59(4):234–5. PMID: 20398584.20398584
Banaschewski T, Soutullo C, Lecendreux M, . Health-related quality of life and functional outcomes from a randomized, controlled study of lisdexamfetamine dimesylate in children and adolescents with attention deficit hyperactivity disorder. CNS Drugs. 2013;27(10):829–40. PMID: 23893527.23893527
Bard DE, Wolraich ML, Neas B, . The psychometric properties of the Vanderbilt attention-deficit hyperactivity disorder diagnostic parent rating scale in a community population. J Dev Behav Pediatr. 2013;34(2):72–82. PMID: 23363972.23363972
Bart O, Raz S and Dan O. Reliability and validity of the Online Continuous Performance Test among children. Assessment. 2014;21(5):637–43. PMID: 24752387.24752387
Battagliese G, Caccetta M, Luppino OI, . Cognitive-behavioral therapy for externalizing disorders: A meta-analysis of treatment effectiveness. Behaviour Research and Therapy. 2015;75:60–71.26575979
Baumeister S, Wolf I, Holz N, . Neurofeedback training effects on inhibitory brain activation in ADHD: A matter of learning?. Neuroscience. 2016. PMID: 27659116.27659116
Bayoumy IM, Khaleel SH, Nada M, . Efficacy and attributes of repetitive transcranial magnetic stimulation (rTMS) in treatment of a sample of children with attention deficit hyperactivity disorder (ADHD). Egyptian Journal of Neurology, Psychiatry and Neurosurgery. 2014;51(3):361–367.
Beauchaine TP, Neuhaus E, Gatzke-Kopp LM, . Electrodermal responding predicts responses to, and may be altered by, preschool intervention for ADHD. J Consult Clin Psychol. 2015;83(2):293–303. PMID: 25486374.25486374
Bedard AC, Schulz KP, Krone B, . Neural mechanisms underlying the therapeutic actions of guanfacine treatment in youth with ADHD: a pilot fMRI study. Psychiatry Res. 2015;231(3):353–6. PMID: 25659477.25659477
Bedard AC, Stein MA, Halperin JM, . Differential impact of methylphenidate and atomoxetine on sustained attention in youth with attention-deficit/hyperactivity disorder. J Child Psychol Psychiatry. 2015;56(1):40–8. PMID: 24942409.24942409
Behdani F, Hebrani P, Naseraee A, . Does omega-3 supplement enhance the therapeutic results of methylphenidate in attention deficit hyperactivity disorder patients?. J Res Med Sci. 2013;18(8):653–8. PMID: 24379840.24379840
Belanger SA, Vanasse M, Spahis S, . Omega-3 fatty acid treatment of children with attention-deficit hyperactivity disorder: A randomized, double-blind, placebo-controlled study. Paediatr Child Health. 2009;14(2):89–98. PMID: 19436468.19436468
Berek M, Kordon A, Hargarter L, . Improved functionality, health related quality of life and decreased burden of disease in patients with ADHD treated with OROS(R) MPH: is treatment response different between children and adolescents?. Child Adolesc Psychiatry Ment Health. 2011;5:26. PMID: 21791096.21791096
Beriault M, Turgeon L, Labrosse M, . Comorbidity of ADHD and Anxiety Disorders in School-Age Children: Impact on Sleep and Response to a Cognitive-Behavioral Treatment. J Atten Disord. 2015. PMID: 26396144.26396144
Beyer von Morgenstern S, Becker I and Sinzig J. Improvement of facial affect recognition in children and adolescents with attention-deficit/hyperactivity disorder under methylphenidate. Acta Neuropsychiatr. 2014;26(4):202–8. PMID: 25142287.25142287
Bishry Z, Ramy HA, El-Shahawi HH, . Screening for ADHD in a Sample of Egyptian Adolescent School Students. J Atten Disord. 2014. PMID: 24891559.24891559
Blader JC, Schooler NR, Jensen PS, . Adjunctive divalproex versus placebo for children with ADHD and aggression refractory to stimulant monotherapy. Am J Psychiatry. 2009;166(12):1392–401. PMID: 19884222.19884222
Bloch MH, Panza KE, Landeros-Weisenberger A, . Meta-analysis: treatment of attention-deficit/hyperactivity disorder in children with comorbid tic disorders. J Am Acad Child Adolesc Psychiatry. 2009;48(9):884–93. PMID: 19625978.19625978
Block SL, Kelsey D, Coury D, . Once-daily atomoxetine for treating pediatric attention-deficit/hyperactivity disorder: comparison of morning and evening dosing. Clin Pediatr (Phila). 2009;48(7):723–33. PMID: 19420182.19420182
Blum NJ, Jawad AF, Clarke AT, . Effect of osmotic-release oral system methylphenidate on different domains of attention and executive functioning in children with attention-deficit-hyperactivity disorder. Dev Med Child Neurol. 2011;53(9):843–9. PMID: 21585365.21585365
Boellner SW, Stark JG, Krishnan S, . Pharmacokinetics of lisdexamfetamine dimesylate and its active metabolite, d-amphetamine, with increasing oral doses of lisdexamfetamine dimesylate in children with attention-deficit/hyperactivity disorder: a single-dose, randomized, open-label, crossover study. Clin Ther. 2010;32(2):252–64. PMID: 20206783.20206783
Bor W, Heath F, Heussler H, . Can a multi-disciplinary assessment approach improve outcomes for children with attention deficit hyperactivity disorder?. Australasian Psychiatry. 2013;21(5):499–503.23897734
Bouwmans C, van der Kolk A, Oppe M, . Validity and responsiveness of the EQ-5D and the KIDSCREEN-10 in children with ADHD. Eur J Health Econ. 2014;15(9):967–77. PMID: 24233919.24233919
Brams M, Turnbow J, Pestreich L, . A randomized, double-blind study of 30 versus 20 mg dexmethylphenidate extended-release in children with attention-deficit/hyperactivity disorder: late-day symptom control. J Clin Psychopharmacol. 2012;32(5):637–44. PMID: 22926597.22926597
Bruchmuller K, Margraf J and Schneider S. Is ADHD diagnosed in accord with diagnostic criteria? Overdiagnosis and influence of client gender on diagnosis. J Consult Clin Psychol. 2012;80(1):128–38. PMID: 22201328.22201328
Bruxel EM, Salatino-Oliveira A, Akutagava-Martins GC, . LPHN3 and attention-deficit/hyperactivity disorder: a susceptibility and pharmacogenetic study. Genes Brain Behav. 2015;14(5):419–27. PMID: 25989180.25989180
Bubnik MG, Hawk LW, Jr., Pelham WE, Jr., . Reinforcement enhances vigilance among children with ADHD: comparisons to typically developing children and to the effects of methylphenidate. J Abnorm Child Psychol. 2015;43(1):149–61. PMID: 24931776.24931776
Buchhorn R, Conzelmann A, Willaschek C, . Heart rate variability and methylphenidate in children with ADHD. Atten Defic Hyperact Disord. 2012;4(2):85–91. PMID: 22328340.22328340
Buitelaar J, Asherson P, Soutullo C, . Differences in maintenance of response upon discontinuation across medication treatments in attention-deficit/hyperactivity disorder. Eur Neuropsychopharmacol. 2015;25(10):1611–21. PMID: 26169574.26169574
Bukstein OG and Head J. Guanfacine ER for the treatment of adolescent attention-deficit/hyperactivity disorder. Expert Opin Pharmacother. 2012;13(15):2207–13. PMID: 22957772.22957772
Burns GL, Servera M, Bernad Mdel M, . Ratings of ADHD symptoms and academic impairment by mothers, fathers, teachers, and aides: construct validity within and across settings as well as occasions. Psychol Assess. 2014;26(4):1247–58. PMID: 24932644.24932644
Bushe CJ and Savill NC. Suicide related events and attention deficit hyperactivity disorder treatments in children and adolescents: a meta-analysis of atomoxetine and methylphenidate comparator clinical trials. Child Adolesc Psychiatry Ment Health. 2013;7:19. PMID: 23777626.23777626
Bussing R, Fernandez M, Harwood M, . Parent and teacher SNAP-IV ratings of attention deficit hyperactivity disorder symptoms: Psychometric properties and normative ratings from a school district sample. Circulation. 2011;124(9):317–328.
Callahan L, Cocozza J, Steadman HJ, . A national survey of U.S. juvenile mental health courts. Psychiatr Serv. 2012;63(2):130–4. PMID: 22302329.22302329
Cannon M, Pelham WH, Sallee FR, . Effects of clonidine and methylphenidate on family quality of life in attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(5):511–7. PMID: 19877975.19877975
Cannon RL. Parietal foci for attention deficit/hyperactivity disorder: Targets for LORETA neurofeedback with outcomes. Biofeedback. 2014;42(2):47–57.
Cantrill A, Wilkes-Gillan S, Bundy A, . An eighteen-month follow-up of a pilot parent-delivered play-based intervention to improve the social play skills of children with attention deficit hyperactivity disorder and their playmates. Australian Occupational Therapy Journal. 2015;62(3):197–207.26058779
Carboni JA, Roach AT and Fredrick LD. Impact of mindfulness training on the behavior of elementary students with attention-deficit/hyperactive disorder. Research in Human Development. 2013;10(3):234–251.
Cardo E, Porsdal V, Quail D, . Fast vs. slow switching from stimulants to atomoxetine in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2013;23(4):252–61. PMID: 23683140.23683140
Chan GFC, Lai KYC, Luk ESL, . Clinical utility of the Chinese Strengths and Weaknesses of ADHD-Symptoms and Normal-behaviors questionnaire (SWAN) when compared with DISC-IV. Neuropsychiatric Disease and Treatment. 2014;10:1533–1542.25187717
Chan GF-C, Lai KY-C, Luk ES-L, . Clinical utility of the Chinese Version of the Strengths and Weaknesses of ADHD-Symptoms and Normal-Behaviors questionnaire (SWAN) when compared with DISC-IV. Neuropsychiatric Disease and Treatment. 2014;10.
Chang Y-K, Hung C-L, Huang C-J, . Effects of an aquatic exercise program on inhibitory control in children with ADHD: A preliminary study. Archives of Clinical Neuropsychology. 2014;29(3):217–223.24695590
Chang YK, Liu S, Yu HH, . Effect of acute exercise on executive function in children with attention deficit hyperactivity disorder. Arch Clin Neuropsychol. 2012;27(2):225–37. PMID: 22306962.22306962
Charach A, Chen S, Hogg-Johnson S, . Using the Conners’ Teacher Rating Scale-Revised in school children referred for assessment. Can J Psychiatry. 2009;54(4):232–41. PMID: 19321029.19321029
Chen TH, Wu SW, Welge JA, . Reduced short interval cortical inhibition correlates with atomoxetine response in children with attention-deficit hyperactivity disorder (ADHD). J Child Neurol. 2014;29(12):1672–9. PMID: 24413361.24413361
Childress AC, Arnold V, Adeyi B, . The effects of lisdexamfetamine dimesylate on emotional lability in children 6 to 12 years of age with ADHD in a double-blind placebo-controlled trial. J Atten Disord. 2014;18(2):123–32. PMID: 22740112.22740112
Childress AC, Brams M, Cutler AJ, . The Efficacy and Safety of Evekeo, Racemic Amphetamine Sulfate, for Treatment of Attention-Deficit/Hyperactivity Disorder Symptoms: A Multicenter, Dose-Optimized, Double-Blind, Randomized, Placebo-Controlled Crossover Laboratory Classroom Study. J Child Adolesc Psychopharmacol. 2015;25(5):402–14. PMID: 25692608.25692608
Childress AC, Spencer T, Lopez F, . Efficacy and safety of dexmethylphenidate extended-release capsules administered once daily to children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(4):351–61. PMID: 19702487.19702487
Childress AC. A critical appraisal of atomoxetine in the management of ADHD. Ther Clin Risk Manag. 2016;12:27–39. PMID: 26730199.26730199
Cho S, Lee SI, Yoo H, . A randomized, open-label assessment of response to various doses of atomoxetine in korean pediatric outpatients with attention-deficit/hyperactivity disorder. Psychiatry Investig. 2011;8(2):141–8. PMID: 21852991.21852991
Choi JW, Han DH, Kang KD, . Aerobic exercise and attention deficit hyperactivity disorder: brain research. Med Sci Sports Exerc. 2015;47(1):33–9. PMID: 24824770.24824770
Chou TL, Chia S, Shang CY, . Differential therapeutic effects of 12-week treatment of atomoxetine and methylphenidate on drug-naive children with attention deficit/hyperactivity disorder: A counting Stroop functional MRI study. Eur Neuropsychopharmacol. 2015. PMID: 26409297.26409297
Chou WJ, Chou MC, Tzang RF, . Better efficacy for the osmotic release oral system methylphenidate among poor adherents to immediate-release methylphenidate in the three ADHD subtypes. Psychiatry Clin Neurosci. 2009;63(2):167–75. PMID: 19335386.19335386
Christiansen H, Reh V, Schmidt MH, . Slow cortical potential neurofeedback and self-management training in outpatient care for children with ADHD: study protocol and first preliminary results of a randomized controlled trial. Front Hum Neurosci. 2014;8:943. PMID: 25505396.25505396
Cockcroft K, Ashwal J and Bentley A. Sleep and daytime sleepiness in methylphenidate medicated and un-medicated children with attention-deficit/hyperactivity disorder (ADHD). Afr J Psychiatry (Johannesbg). 2009;12(4):275–9. PMID: 20033109.20033109
Coelho LF, Barbosa DLF, Rizzutti S, . Use of cognitive behavioral therapy and token economy to alleviate dysfunctional behavior in children with attention-deficit hyperactivity disorder. Frontiers in Psychiatry. 2015;6(NOV).
Coghill D, Banaschewski T, Lecendreux M, . European, randomized, phase 3 study of lisdexamfetamine dimesylate in children and adolescents with attention-deficit/hyperactivity disorder. Eur Neuropsychopharmacol. 2013;23(10):1208–18. PMID: 23332456.23332456
Coghill DR, Banaschewski T, Lecendreux M, . Efficacy of lisdexamfetamine dimesylate throughout the day in children and adolescents with attention-deficit/hyperactivity disorder: results from a randomized, controlled trial. Eur Child Adolesc Psychiatry. 2014;23(2):61–8. PMID: 23708466.23708466
Coghill DR, Banaschewski T, Lecendreux M, . Maintenance of efficacy of lisdexamfetamine dimesylate in children and adolescents with attention-deficit/hyperactivity disorder: randomized-withdrawal study design. J Am Acad Child Adolesc Psychiatry. 2014;53(6):647–657.e1. PMID: 24839883.24839883
Coghill DR, Banaschewski T, Lecendreux M, . Post hoc analyses of the impact of previous medication on the efficacy of lisdexamfetamine dimesylate in the treatment of attention-deficit/hyperactivity disorder in a randomized, controlled trial. Neuropsychiatr Dis Treat. 2014;10:2039–47. PMID: 25378930.25378930
Cohen SC, Mulqueen JM, Ferracioli-Oda E, . Meta-Analysis: Risk of Tics Associated With Psychostimulant Use in Randomized, Placebo-Controlled Trials. J Am Acad Child Adolesc Psychiatry. 2015;54(9):728–36. PMID: 26299294.26299294
Cohen-Yavin I, Yoran-Hegesh R, Strous RD, . Efficacy of reboxetine in the treatment of attention-deficit/hyperactivity disorder in boys with intolerance to methylphenidate: an open-label, 8-week, methylphenidate-controlled trial. Clin Neuropharmacol. 2009;32(4):179–82. PMID: 19644227.19644227
Coker TR, Elliott MN, Toomey SL, . Racial and ethnic disparities in ADHD diagnosis and treatment. Pediatrics. 2016;138(3).
Connor DF, Findling RL, Kollins SH, . Effects of guanfacine extended release on oppositional symptoms in children aged 6–12 years with attention-deficit hyperactivity disorder and oppositional symptoms: a randomized, double-blind, placebo-controlled trial. CNS Drugs. 2010;24(9):755–68. PMID: 20806988.20806988
Conzelmann A, Gerdes AB, Mucha RF, . Autonomic hypoactivity in boys with attention-deficit/hyperactivity disorder and the influence of methylphenidate. World J Biol Psychiatry. 2014;15(1):56–65. PMID: 24410179.24410179
Cook A, Johnson C and Bradley-Johnson S. White noise to decrease problem behaviors in the classroom for a child with Attention Deficit Hyperactivity Disorder (ADHD). Child & Family Behavior Therapy. 2015;37(1):38–50.
Coon ER, Quinonez RA, Moyer VA, . Overdiagnosis: how our compulsion for diagnosis may be harming children. Pediatrics. 2014;134(5):1013–23. PMID: 25287462.25287462
Cordier R, Munro N, Wilkes-Gillan S, . The pragmatic language abilities of children with ADHD following a play-based intervention involving peer-to-peer interactions. Int J Speech Lang Pathol. 2013;15(4):416–28. PMID: 22974071.22974071
Coughlin CG, Cohen SC, Mulqueen JM, . Meta-Analysis: Reduced Risk of Anxiety with Psychostimulant Treatment in Children with Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2015;25(8):611–7. PMID: 26402485.26402485
Cubero-Millan I, Molina-Carballo A, Machado-Casas I, . Methylphenidate ameliorates depressive comorbidity in ADHD children without any modification on differences in serum melatonin concentration between ADHD subtypes. Int J Mol Sci. 2014;15(9):17115–29. PMID: 25257531.25257531
Curchack-Lichtin JT, Chacko A and Halperin JM. Changes in ADHD symptom endorsement: preschool to school age. J Abnorm Child Psychol. 2014;42(6):993–1004. PMID: 24343794.24343794
Cutler AJ, Brams M, Bukstein O, . Response/remission with guanfacine extended-release and psychostimulants in children and adolescents with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2014;53(10):1092–101. PMID: 25245353.25245353
Cuypers K, De Ridder K and Strandheim A. The effect of therapeutic horseback riding on 5 children with attention deficit hyperactivity disorder: a pilot study. J Altern Complement Med. 2011;17(10):901–8. PMID: 22010778.22010778
Daley D and O’Brien M. A small-scale randomized controlled trial of the self-help version of the New Forest Parent Training Programme for children with ADHD symptoms. Eur Child Adolesc Psychiatry. 2013;22(9):543–52. PMID: 23463179.23463179
Dalsgaard S, Kvist AP, Leckman JF, . Cardiovascular safety of stimulants in children with attention-deficit/hyperactivity disorder: a nationwide prospective cohort study. J Child Adolesc Psychopharmacol. 2014;24(6):302–10. PMID: 24956171.24956171
Dalsgaard S, Leckman JF, Nielsen HS, . Gender and injuries predict stimulant medication use. J Child Adolesc Psychopharmacol. 2014;24(5):253–9. PMID: 24813570.24813570
Daniels B, Volpe RJ, Briesch AM, . Development of a problem-focused behavioral screener linked to evidence-based intervention. Sch Psychol Q. 2014;29(4):438–51. PMID: 25485466.25485466
Dashti N, Hekmat H, Soltani HR, . Comparison of therapeutic effects of omega-3 and methylphenidate (ritalin((R))) in treating children with attention deficit hyperactivity disorder. Iran J Psychiatry Behav Sci. 2014;8(4):7–11. PMID: 25798168.25798168
Davari-Ashtiani R, Shahrbabaki ME, Razjouyan K, . Buspirone versus methylphenidate in the treatment of attention deficit hyperactivity disorder: a double-blind and randomized trial. Child Psychiatry Hum Dev. 2010;41(6):641–8. PMID: 20517641.20517641
Deans P, O’Laughlin L, Brubaker B, . Use of eye movement tracking in the differential diagnosis of Attention Deficit Hyperactivity Disorder (ADHD) and reading disability. Psychology. 2010;1(4):238–246.
Dell’Agnello G, Maschietto D, Bravaccio C, . Atomoxetine hydrochloride in the treatment of children and adolescents with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder: A placebo-controlled Italian study. Eur Neuropsychopharmacol. 2009;19(11):822–34. PMID: 19716683.19716683
Devena SE and Watkins MW. Diagnostic utility of WISC-IV general abilities index and cognitive proficiency index difference scores among children with ADHD. Journal of Applied School Psychology. 2012;28(2):133–154.
Dickson RA, Maki E, Gibbins C, . Time courses of improvement and symptom remission in children treated with atomoxetine for attention-deficit/hyperactivity disorder: analysis of Canadian open-label studies. Child Adolesc Psychiatry Ment Health. 2011;5:14. PMID: 21569378.21569378
Dittmann RW, Cardo E, Nagy P, . Efficacy and safety of lisdexamfetamine dimesylate and atomoxetine in the treatment of attention-deficit/hyperactivity disorder: a head-to-head, randomized, double-blind, phase IIIb study. CNS Drugs. 2013;27(12):1081–92. PMID: 23959815.23959815
Dittmann RW, Cardo E, Nagy P, . Treatment response and remission in a double-blind, randomized, head-to-head study of lisdexamfetamine dimesylate and atomoxetine in children and adolescents with attention-deficit hyperactivity disorder. CNS Drugs. 2014;28(11):1059–69. PMID: 25038977.25038977
Dittmann RW, Schacht A, Helsberg K, . Atomoxetine versus placebo in children and adolescents with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder: a double-blind, randomized, multicenter trial in Germany. J Child Adolesc Psychopharmacol. 2011;21(2):97–110. PMID: 21488751.21488751
Docking K, Munro N, Cordier R, . Examining the language skills of children with ADHD following a play-based intervention. Child Language Teaching and Therapy. 2013;29(3):291–304.
Döpfner M, Ise E, Wolff Metternich-Kaizman T, . Adaptive multimodal treatment for children with attention-deficit-/hyperactivity disorder: An 18 month follow-up. Child Psychiatry and Human Development. 2015;46(1):44–56.24638884
Dopfner M, Ose C, Fischer R, . Comparison of the efficacy of two different modified release methylphenidate preparations for children and adolescents with attention-deficit/hyperactivity disorder in a natural setting: comparison of the efficacy of Medikinet((R)) retard and Concerta((R))--a randomized, controlled, double-blind multicenter clinical crossover trial. J Child Adolesc Psychopharmacol. 2011;21(5):445–54. PMID: 21790298.21790298
Dubnov-Raz G, Khoury Z, Wright I, . The effect of alpha-linolenic acid supplementation on ADHD symptoms in children: a randomized controlled double-blind study. Front Hum Neurosci. 2014;8:780. PMID: 25339885.25339885
DuPaul GJ, Kern L, Gormley MJ, . Early intervention for young children with ADHD: Academic outcomes for responders to behavioral treatment. School Mental Health. 2011;3(3):117–126. PMID: 2011-18575-002.
Durand-Rivera A, Alatorre-Miguel E, Zambrano-Sánchez E, . Methylphenidate efficacy: Immediate versus extended release at short term in mexican children with ADHD assessed by conners scale and EEG. Neurology Research International 2015;2015.
Edwards C and Howlett E. Putting knowledge to trial: ‘ADHD parents’ and the evaluation of alternative therapeutic regimes. Soc Sci Med. 2013;81:34–41. PMID: 23422058.23422058
Edwards MC and Sigel BA. Estimates of the Utility of Child Behavior Checklist/Teacher Report Form Attention Problems Scale in the Diagnosis of ADHD in Children Referred to a Specialty Clinic. Journal of Psychopathology and Behavioral Assessment. 2015;37(1):50–59.
Efron D, Sciberras E, Anderson V, . Functional status in children with ADHD at age 6–8: a controlled community study. Pediatrics. 2014;134(4):e992–e1000. PMID: 25266432.25266432
El Baza F, AlShahawi HA, Zahra S, . Magnesium supplementation in children with attention deficit hyperactivity disorder. Egyptian Journal of Medical Human Genetics. 2015.
Elliott GR, Blasey C, Rekshan W, . Cognitive Testing to Identify Children With ADHD Who Do and Do Not Respond to Methylphenidate. J Atten Disord. 2014. PMID: 25122732.25122732
Epstein JN, Brinkman WB, Froehlich T, . Effects of stimulant medication, incentives, and event rate on reaction time variability in children with ADHD. Neuropsychopharmacology. 2011;36(5):1060–72. PMID: 21248722.21248722
Epstein JN, Kelleher KJ, Baum R, . Variability in ADHD care in community-based pediatrics. Pediatrics. 2014;134(6):1136–43. PMID: 25367532.25367532
Erder MH, Xie J, Signorovitch JE, . Cost effectiveness of guanfacine extended-release versus atomoxetine for the treatment of attention-deficit/hyperactivity disorder: application of a matching-adjusted indirect comparison. Appl Health Econ Health Policy. 2012;10(6):381–95. PMID: 23113551.23113551
Escobar R, Montoya A, Polavieja P, . Evaluation of patients’ and parents’ quality of life in a randomized placebo-controlled atomoxetine study in attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(3):253–63. PMID: 19519260.19519260
Evans SW, Schultz BK, Demars CE, . Effectiveness of the Challenging Horizons After-School Program for young adolescents with ADHD. Behav Ther. 2011;42(3):462–74. PMID: 21658528.21658528
Fabiano GA, Vujnovic RK, Pelham WE, . Enhancing the effectiveness of special education programming for children with attention deficit hyperactivity disorder using a daily report card. School Psychology Review. 2010;39(2):219–239.
Faedda GL, Ohashi K, Hernandez M, . Actigraph measures discriminate pediatric bipolar disorder from attention-deficit/hyperactivity disorder and typically developing controls. J Child Psychol Psychiatry. 2016;57(6):706–16. PMID: 26799153.26799153
Faraone SV, Glatt SJ, Bukstein OG, . Effects of once-daily oral and transdermal methylphenidate on sleep behavior of children with ADHD. J Atten Disord. 2009;12(4):308–15. PMID: 18400982.18400982
Faraone SV, Newcorn JH, Antshel KM, . The Groundskeeper Gaming Platform as a Diagnostic Tool for Attention-Deficit/Hyperactivity Disorder: Sensitivity, Specificity, and Relation to Other Measures. J Child Adolesc Psychopharmacol. 2016. PMID: 27105181.27105181
Farmer CA, Brown NV, Gadow KD, . Comorbid symptomatology moderates response to risperidone, stimulant, and parent training in children with severe aggression, disruptive behavior disorder, and attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2015;25(3):213–24. PMID: 25885011.25885011
Fernandes Azevedo A, Seabra-Santos MJ, Gaspar MF, . A parent-based intervention programme involving preschoolers with AD/HD behaviours: are children’s and mothers’ effects sustained over time?. Eur Child Adolesc Psychiatry. 2014;23(6):437–50. PMID: 23999733.23999733
Findling RL, Adeyi B, Dirks B, . Parent-reported executive function behaviors and clinician ratings of attention-deficit/hyperactivity disorder symptoms in children treated with lisdexamfetamine dimesylate. J Child Adolesc Psychopharmacol. 2013;23(1):28–35. PMID: 23410139.23410139
Findling RL, Childress AC, Cutler AJ, . Efficacy and safety of lisdexamfetamine dimesylate in adolescents with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2011;50(4):395–405. PMID: 21421179.21421179
Findling RL, McBurnett K, White C, . Guanfacine extended release adjunctive to a psychostimulant in the treatment of comorbid oppositional symptoms in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2014;24(5):245–52. PMID: 24945085.24945085
Findling RL, Turnbow J, Burnside J, . A randomized, double-blind, multicenter, parallel-group, placebo-controlled, dose-optimization study of the methylphenidate transdermal system for the treatment of ADHD in adolescents. CNS Spectr. 2010;15(7):419–30. PMID: 20625364.20625364
Fosco WD, White CN and Hawk LW, Jr. Acute Stimulant Treatment and Reinforcement Increase the Speed of Information Accumulation in Children with ADHD. J Abnorm Child Psychol. 2016. PMID: 27787672.27787672
Fox O, Adi-Japha E and Karni A. The effect of a skipped dose (placebo) of methylphenidate on the learning and retention of a motor skill in adolescents with Attention Deficit Hyperactivity Disorder. Eur Neuropsychopharmacol. 2014;24(3):391–6. PMID: 24332892.24332892
Funabiki Y, Kawagishi H, Uwatoko T, . Development of a multi-dimensional scale for PDD and ADHD. Res Dev Disabil. 2011;32(3):995–1003. PMID: 21353761.21353761
Gadow KD and Nolan EE. Methylphenidate and comorbid anxiety disorder in children with both chronic multiple tic disorder and ADHD. J Atten Disord. 2011;15(3):246–56. PMID: 20378921.20378921
Garcia SP, Guimaraes J, Zampieri JF, . Response to methylphenidate in children and adolescents with ADHD: does comorbid anxiety disorders matters?. J Neural Transm (Vienna). 2009;116(5):631–6. PMID: 19370390.19370390
Garcia-Barrera MA, Karr JE, Duran V, . Cross-Cultural Validation of a Behavioral Screener for Executive Functions: Guidelines for Clinical Use Among Colombian Children With and Without ADHD. Psychological Assessment. 2015.
Garcia-Gomez A, Rodriguez-Jimenez M, Guerrero-Barona E, . Benefits of an experimental program of equestrian therapy for children with ADHD. Res Dev Disabil. 2016;59:176–185. PMID: 27614276.27614276
Garg J, Arun P and Chavan BS. Comparative efficacy of methylphenidate and atomoxetine in oppositional defiant disorder comorbid with attention deficit hyperactivity disorder. Int J Appl Basic Med Res. 2015;5(2):114–8. PMID: 26097819.26097819
Garg J, Arun P and Chavan BS. Comparative short term efficacy and tolerability of methylphenidate and atomoxetine in attention deficit hyperactivity disorder. Indian Pediatr. 2014;51(7):550–4. PMID: 25031133.25031133
Garnock-Jones KP and Keating GM. Spotlight on atomoxetine in attention-deficit hyperactivity disorder in children and adolescents. CNS Drugs. 2010;24(1):85–8. PMID: 20030421.20030421
Gau SS, Ni HC, Shang CY, . Psychiatric comorbidity among children and adolescents with and without persistent attention-deficit hyperactivity disorder. Aust N Z J Psychiatry. 2010;44(2):135–43. PMID: 20113302.20113302
Georgiopoulos AM and Hua LL. The diagnosis and treatment of attention deficit-hyperactivity disorder in children and adolescents with cystic fibrosis: a retrospective study. Psychosomatics. 2011;52(2):160–6. PMID: 21397109.21397109
Gerber WD, Gerber-von Muller G, Andrasik F, . The impact of a multimodal Summer Camp Training on neuropsychological functioning in children and adolescents with ADHD: an exploratory study. Child Neuropsychol. 2012;18(3):242–55. PMID: 21824010.21824010
Gerdes AC, Kapke TL, Lawton KE, . Culturally adapting parent training for Latino youth with ADHD: Development and pilot. Journal of Latina/o Psychology. 2015;3(2):71–87. PMID: 2015-18959-001.
Ghanizadeh A, Sayyari Z and Mohammadi MR. Effect of methylphenidate and folic Acid on ADHD symptoms and quality of life and aggression: a randomized double blind placebo controlled clinical trial. Iran J Psychiatry. 2013;8(3):108–12. PMID: 24454418.24454418
Gharebaghy S, Rassafiani M and Cameron D. Effect of cognitive intervention on children with ADHD. Phys Occup Ther Pediatr. 2015;35(1):13–23. PMID: 25246134.25246134
Giana G, Romano E, Porfirio MC, . Detection of auto-antibodies to DAT in the serum: interactions with DAT genotype and psycho-stimulant therapy for ADHD. J Neuroimmunol. 2015;278:212–22. PMID: 25468771.25468771
Giblin JM and Strobel AL. Effect of lisdexamfetamine dimesylate on sleep in children with ADHD. J Atten Disord. 2011;15(6):491–8. PMID: 20574056.20574056
Gibson BS, Gondoli DM, Johnson AC, . Component analysis of verbal versus spatial working memory training in adolescents with ADHD: a randomized, controlled trial. Child Neuropsychol. 2011;17(6):546–63. PMID: 21390920.21390920
Gill KE, Chappell AM, Beveridge TJR, . Chronic methylphenidate treatment during early life is associated with greater ethanol intake in socially isolated rats. Alcoholism: Clinical and Experimental Research. 2014;38(8):2260–2268.
Goez HR, Scott O, Nevo N, . Using the test of variables of attention to determine the effectiveness of modafinil in children with attention-deficit hyperactivity disorder (ADHD): a prospective methylphenidate-controlled trial. J Child Neurol. 2012;27(12):1547–52. PMID: 22447850.22447850
Gonzalez-Heydrich J, Whitney J, Waber D, . Adaptive phase I study of OROS methylphenidate treatment of attention deficit hyperactivity disorder with epilepsy. Epilepsy Behav. 2010;18(3):229–37. PMID: 20493783.20493783
Gray KM, Riggs PD, Min SJ, . Cigarette and cannabis use trajectories among adolescents in treatment for attention-deficit/hyperactivity disorder and substance use disorders. Drug Alcohol Depend. 2011;117(2–3):242–7. PMID: 21411243.21411243
Gray L, Miller BS and Evans SW. Training children with ADHD to minimize impulsivity in auditory contralateral masking. Int J Pediatr Otorhinolaryngol. 2012;76(4):483–7. PMID: 22297209.22297209
Graziano PA, Geffken GR and Lall AS. Heterogeneity in the pharmacological treatment of children with ADHD: cognitive, behavioral, and social functioning differences. J Atten Disord. 2011;15(5):382–91. PMID: 20495162.20495162
Green CT, Long DL, Green D, . Will working memory training generalize to improve off-task behavior in children with attention-deficit/hyperactivity disorder?. Neurotherapeutics. 2012;9(3):639–48. PMID: 22752960.22752960
Green JG, Avenevoli S, Finkelman M, . Attention deficit hyperactivity disorder: concordance of the adolescent version of the Composite International Diagnostic Interview Version 3.0 (CIDI) with the K-SADS in the US National Comorbidity Survey Replication Adolescent (NCS-A) supplement. Int J Methods Psychiatr Res. 2010;19(1):34–49. PMID: 20191660.20191660
Grizenko N, Cai E, Jolicoeur C, . Effects of methylphenidate on acute math performance in children with attention-deficit hyperactivity disorder. Can J Psychiatry. 2013;58(11):632–9. PMID: 24246434.24246434
Grizenko N, Qi Zhang DD, Polotskaia A, . Efficacy of Methylphenidate in ADHD Children across the Normal and the Gifted Intellectual Spectrum. J Can Acad Child Adolesc Psychiatry. 2012;21(4):282–8. PMID: 23133462.23133462
Grizenko N, Zhang DDQ, Polotskaia A, . Effcacy of methylphenidate in ADHD children across the normal and the gifted intellectual spectrum. Journal of the Canadian Academy of Child and Adolescent Psychiatry. 2012;21(4):282–288.23133462
Groom MJ, Scerif G, Liddle PF, . Effects of motivation and medication on electrophysiological markers of response inhibition in children with attention-deficit/hyperactivity disorder. Biological Psychiatry. 2010;67(7):624–631.19914599
Guertin J, LeLorier J, Durand M, . Impact of a restrictive drug access program on the risk of cardiovascular encounters in children exposed to ADHD medications. J Popul Ther Clin Pharmacol. 2014;21(3):e357–69. PMID: 25326915.25326915
Gunther T, Herpertz-Dahlmann B and Konrad K. Sex differences in attentional performance and their modulation by methylphenidate in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2010;20(3):179–86. PMID: 20578930.20578930
Gunther T, Kahraman-Lanzerath B, Knospe EL, . Modulation of attention-deficit/hyperactivity disorder symptoms by short- and long-acting methylphenidate over the course of a day. J Child Adolesc Psychopharmacol. 2012;22(2):131–8. PMID: 22364402.22364402
Gupta K and Mamidi P. A comparative study on Naladadi Ghrita in attention-deficit/hyperactivity disorder with Kushmanda Ghrita. International Journal of Green Pharmacy. 2013;7(4):322–327.
Haack LM, Villodas MT, McBurnett K, . Parenting Mediates Symptoms and Impairment in Children With ADHD-Inattentive Type. J Clin Child Adolesc Psychol. 2014:1–12. PMID: 25411896.25411896
Haertling F, Mueller B and Bilke-Hentsch O. Effectiveness and safety of a long-acting, once-daily, two-phase release formulation of methylphenidate (Ritalin (R) LA) in school children under daily practice conditions. Atten Defic Hyperact Disord. 2015;7(2):157–64. PMID: 25346231.25346231
Haghshenas S, Hosseini MS and Aminjan AS. A possible correlation between vestibular stimulation and auditory comprehension in children with attention-deficit/hyperactivity disorder. Psychology and Neuroscience. 2014;7(2):159–162.
Hahn-Markowitz J, Manor I and Maeir A. Effectiveness of cognitive-functional (Cog-Fun) intervention with children with attention deficit hyperactivity disorder: a pilot study. Am J Occup Ther. 2011;65(4):384–92. PMID: 21834453.21834453
Hailpern SM, Egan BM, Lewis KD, . Blood Pressure, Heart Rate, and CNS Stimulant Medication Use in Children with and without ADHD: Analysis of NHANES Data. Front Pediatr. 2014;2:100. PMID: 25285304.25285304
Hale JB, Reddy LA, Semrud-Clikeman M, . Executive impairment determines ADHD medication response: implications for academic achievement. J Learn Disabil. 2011;44(2):196–212. PMID: 21383110.21383110
Hall CL, Walker GM, Valentine AZ, . Protocol investigating the clinical utility of an objective measure of activity and attention (QbTest) on diagnostic and treatment decision-making in children and young people with ADHD-’Assessing QbTest Utility in ADHD’ (AQUA): a randomised controlled trial. BMJ Open. 2014;4(12):e006838. PMID: 25448628.25448628
Hamidovic A, Dlugos A, Palmer AA, . Polymorphisms in dopamine transporter (SLC6A3) are associated with stimulant effects of D-amphetamine: an exploratory pharmacogenetic study using healthy volunteers. Behav Genet. 2010;40(2):255–61. PMID: 20091113.20091113
Hammer R, Cooke GE, Stein MA, . Functional neuroimaging of visuospatial working memory tasks enables accurate detection of attention deficit and hyperactivity disorder. NeuroImage: Clinical. 2015;9:244–252.26509111
Hammerness P, Georgiopoulos A, Doyle RL, . An open study of adjunct OROS-methylphenidate in children who are atomoxetine partial responders: II. Tolerability and pharmacokinetics. J Child Adolesc Psychopharmacol. 2009;19(5):493–9. PMID: 19877973.19877973
Hannesdottir DK, Ingvarsdottir E and Bjornsson A. The OutSMARTers Program for Children With ADHD: A Pilot Study on the Effects of Social Skills, Self-Regulation, and Executive Function Training. J Atten Disord. 2014. PMID: 24505061.24505061
Hantson J, Wang PP, Grizenko-Vida M, . Effectiveness of a therapeutic summer camp for children with ADHD: Phase I Clinical Intervention Trial. J Atten Disord. 2012;16(7):610–7. PMID: 21856955.21856955
Harfterkamp M, van de Loo-Neus G, Minderaa RB, . A randomized double-blind study of atomoxetine versus placebo for attention-deficit/hyperactivity disorder symptoms in children with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. 2012;51(7):733–41. PMID: 22721596.22721596
Hartanto TA, Krafft CE, Iosif AM, . A trial-by-trial analysis reveals more intense physical activity is associated with better cognitive control performance in attention-deficit/hyperactivity disorder. Child Neuropsychol. 2015:1–9. PMID: 26059476.26059476
Hashemian P and Nazemian A. Evaluation of bupropion and venlafaxine in children with ADHD. African Journal of Psychiatry (South Africa). 2015;18(2).
Hautmann C, Rothenberger A and Dopfner M. An observational study of response heterogeneity in children with attention deficit hyperactivity disorder following treatment switch to modified-release methylphenidate. BMC Psychiatry. 2013;13:219. PMID: 24004962.24004962
Hautmann C, Rothenberger A and Dopfner M. Daily Symptom Profiles of Children With ADHD Treated With Modified-Release Methylphenidate: An Observational Study. J Atten Disord. 2013. PMID: 24062276.24062276
Haydicky J, Shecter C, Wiener J, . Evaluation of MBCT for adolescents with ADHD and their parents: Impact on individual and family functioning. Journal of Child and Family Studies. 2015;24(1):76–94.
Haydicky J, Wiener J, Badali P, . Evaluation of a mindfulness-based intervention for adolescents with learning disabilities and co-occurring ADHD and anxiety. Mindfulness. 2012;3(2):151–164.
Hazell PL, Kohn MR, Dickson R, . Core ADHD symptom improvement with atomoxetine versus methylphenidate: a direct comparison meta-analysis. J Atten Disord. 2011;15(8):674–83. PMID: 20837981.20837981
Heinrich H, Busch K, Studer P, . Refining the picture of reduced alerting responses in ADHD - a single-trial analysis of event-related potentials. Neurosci Lett. 2014;582:49–53. PMID: 25218713.25218713
Helgadottir H, Gudmundsson OO, Baldursson G, . Electroencephalography as a clinical tool for diagnosing and monitoring attention deficit hyperactivity disorder: a cross-sectional study. BMJ Open. 2015;5(1):e005500. PMID: 25596195.25596195
Heller MD, Roots K, Srivastava S, . A Machine Learning-Based Analysis of Game Data for Attention Deficit Hyperactivity Disorder Assessment. Games Health J. 2013;2(5):291–8. PMID: 26196929.26196929
Hellwig-Brida S, Daseking M, Keller F, . Effects of methylphenidate on intelligence and attention components in boys with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2011;21(3):245–53. PMID: 21663427.21663427
Hervas A, Huss M, Johnson M, . Efficacy and safety of extended-release guanfacine hydrochloride in children and adolescents with attention-deficit/hyperactivity disorder: a randomized, controlled, phase III trial. Eur Neuropsychopharmacol. 2014;24(12):1861–72. PMID: 25453486.25453486
Hirayama S, Terasawa K, Rabeler R, . The effect of phosphatidylserine administration on memory and symptoms of attention-deficit hyperactivity disorder: a randomised, double-blind, placebo-controlled clinical trial. J Hum Nutr Diet. 2014;27(Suppl 2):284–91. PMID: 23495677.23495677
Holzer B, Lopes V and Lehman R. Combination use of atomoxetine hydrochloride and olanzapine in the treatment of attention-deficit/hyperactivity disorder with comorbid disruptive behavior disorder in children and adolescents 10–18 years of age. J Child Adolesc Psychopharmacol. 2013;23(6):415–8. PMID: 23952189.23952189
Hong M, Lee WH, Moon DS, . A 36 month naturalistic retrospective study of clinic-treated youth with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2014;24(6):341–6. PMID: 24955936.24955936
Hosainzadeh Maleki Z, Mashhadi A, Soltanifar A, . Barkley’s Parent Training Program, Working Memory Training and their Combination for Children with ADHD: Attention Deficit Hyperactivity Disorder. Iran J Psychiatry. 2014;9(2):47–54. PMID: 25632280.25632280
Iannaccone R, Hauser TU, Ball J, . Classifying adolescent attention-deficit/hyperactivity disorder (ADHD) based on functional and structural imaging. Eur Child Adolesc Psychiatry. 2015;24(10):1279–89. PMID: 25613588.25613588
Ince Tasdelen B, Karakaya E and Oztop DB. Effects of Atomoxetine and Osmotic Release Oral System-Methylphenidate on Executive Functions in Patients with Combined Type Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2015;25(6):494–500. PMID: 26218871.26218871
Ironside S, Davidson F and Corkum P. Circadian motor activity affected by stimulant medication in children with attention-deficit/hyperactivity disorder. J Sleep Res. 2010;19(4):546–51. PMID: 20629940.20629940
Isaksson J, Nilsson KW and Lindblad F. The Pressure-Activation-Stress scale in relation to ADHD and cortisol. Eur Child Adolesc Psychiatry. 2015;24(2):153–61. PMID: 24737123.24737123
Iseman JS and Naglieri JA. A cognitive strategy instruction to improve math calculation for children with ADHD and LD: a randomized controlled study. J Learn Disabil. 2011;44(2):184–95. PMID: 21383109.21383109
Jafari N, Mohammadi MR, Khanbani M, . Effect of play therapy on behavioral problems of maladjusted preschool children. Iran J Psychiatry. 2011;6(1):37–42. PMID: 22952519.22952519
Jafarinia M, Mohammadi MR, Modabbernia A, . Bupropion versus methylphenidate in the treatment of children with attention-deficit/hyperactivity disorder: randomized double-blind study. Hum Psychopharmacol. 2012;27(4):411–8. PMID: 22806822.22806822
Jain R, Babcock T, Burtea T, . Efficacy and safety of lisdexamfetamine dimesylate in children with attention-deficit/hyperactivity disorder and recent methylphenidate use. Adv Ther. 2013;30(5):472–86. PMID: 23681505.23681505
Jain R, Babcock T, Burtea T, . Efficacy of lisdexamfetamine dimesylate in children with attention-deficit/hyperactivity disorder previously treated with methylphenidate: a post hoc analysis. Child Adolesc Psychiatry Ment Health. 2011;5(1):35. PMID: 22054243.22054243
Jain R, Segal S, Kollins SH, . Clonidine extended-release tablets for pediatric patients with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2011;50(2):171–9. PMID: 21241954.21241954
Janssen M, Wensing M, van der Gaag RJ, . Improving patient care for attention deficit hyperactivity disorder in children by organizational redesign (Tornado program) and enhanced collaboration between psychiatry and general practice: a controlled before and after study. Implement Sci. 2014;9:155. PMID: 25359002.25359002
Jensen LS, Pagsberg AK and Dalhoff KP. Differences in abuse potential of ADHD drugs measured by contrasting poison centre and therapeutic use data. Clin Toxicol (Phila). 2015;53(4):210–4. PMID: 25738696.25738696
Johnson KA, Barry E, Lambert D, . Methylphenidate side effect profile is influenced by genetic variation in the attention-deficit/hyperactivity disorder-associated CES1 gene. J Child Adolesc Psychopharmacol. 2013;23(10):655–64. PMID: 24350812.24350812
Johnston C, Weiss MD, Murray C, . The effects of instructions on mothers’ ratings of attention-deficit/hyperactivity disorder symptoms in referred children. J Abnorm Child Psychol. 2014;42(3):479–88. PMID: 23963544.23963544
Johnstone SJ, Roodenrys S, Phillips E, . A pilot study of combined working memory and inhibition training for children with AD/HD. Atten Defic Hyperact Disord. 2010;2(1):31–42. PMID: 21432588.21432588
Jonkman LM, Hurks PP and Schleepen TM. Effects of memory strategy training on performance and event-related brain potentials of children with ADHD in an episodic memory task. Neuropsychol Rehabil. 2015:1–32. PMID: 26251965.26251965
Kahbazi M, Ghoreishi A, Rahiminejad F, . A randomized, double-blind and placebo-controlled trial of modafinil in children and adolescents with attention deficit and hyperactivity disorder. Psychiatry Res. 2009;168(3):234–7. PMID: 19439364.19439364
Kaiser ML, Schoemaker MM, Albaret JM, . What is the evidence of impaired motor skills and motor control among children with attention deficit hyperactivity disorder (ADHD)? Systematic review of the literature. Res Dev Disabil. 2014;36c:338–357. PMID: 25462494.25462494
Katic A, Dirks B, Babcock T, . Treatment outcomes with lisdexamfetamine dimesylate in children who have attention-deficit/hyperactivity disorder with emotional control impairments. J Child Adolesc Psychopharmacol. 2013;23(6):386–93. PMID: 23952185.23952185
Katzmann J, Hautmann C, Greimel L, . Behavioral and Nondirective Guided Self-Help for Parents of Children with Externalizing Behavior: Mediating Mechanisms in a Head-To-Head Comparison. J Abnorm Child Psychol. 2016. PMID: 27488368.27488368
Kean JD, Kaufman J, Lomas J, . A Randomized Controlled Trial Investigating the Effects of a Special Extract of Bacopa monnieri (CDRI 08) on Hyperactivity and Inattention in Male Children and Adolescents: BACHI Study Protocol (ANZCTRN12612000827831). Nutrients. 2015;7(12):9931–45. PMID: 26633481.26633481
Kendall L. ‘The teacher said I’m thick!’ Experiences of children with Attention Deficit Hyperactivity Disorder within a school setting. Support for Learning. 2016;31(2):122–137.
Kennel S, Taylor AG, Lyon D, . Pilot feasibility study of binaural auditory beats for reducing symptoms of inattention in children and adolescents with attention-deficit/hyperactivity disorder. J Pediatr Nurs. 2010;25(1):3–11. PMID: 20117669.20117669
Keshavarzi Z, Bajoghli H, Mohamadi MR, . In a randomized case-control trial with 10-years olds suffering from attention deficit/hyperactivity disorder (ADHD) sleep and psychological functioning improved during a 12-week sleep-training program. World J Biol Psychiatry. 2014;15(8):609–19. PMID: 24957753.24957753
Khanna D, Shaw J, Dolan M, . Does diagnosis affect the predictive accuracy of risk assessment tools for juvenile offenders: Conduct Disorder and Attention Deficit Hyperactivity Disorder. J Adolesc. 2014;37(7):1171–9. PMID: 25173178.25173178
Kim BN, Kim YN, Cheong US, . Switching from methylphenidate-immediate release (MPH-IR) to methylphenidate-OROS (OROS-MPH): A multi-center, open-label study in Korea. Clinical Psychopharmacology and Neuroscience. 2011;9(1):29–35.23430964
Kim JW, Park S, Kim BN, . Parental perceived benefits of OROS-methylphenidate treatment for the child with attention-deficit/hyperactivity disorder and for parents themselves. Pharmacopsychiatry. 2013;46(4):137–46. PMID: 23364873.23364873
Kim JW, Sharma V and Ryan ND. Predicting Methylphenidate Response in ADHD Using Machine Learning Approaches Int J Neuropsychopharmacol. 2015;18(11). PMID: 25964505.25964505
Klein RG, Mannuzza S, Olazagasti MAR, . Clinical and functional outcome of childhood attention-deficit/hyperactivity disorder 33 years later. JAMA Psychiatry. 2012;69(12):1295–1303.
Knebel W, Rogers J, Polhamus D, . Modeling and simulation of the exposure-response and dropout pattern of guanfacine extended-release in pediatric patients with ADHD. J Pharmacokinet Pharmacodyn. 2015;42(1):45–65. PMID: 25373474.25373474
Kollins SH, Jain R, Brams M, . Clonidine extended-release tablets as add-on therapy to psychostimulants in children and adolescents with ADHD. Pediatrics. 2011;127(6):e1406–13. PMID: 21555501.21555501
Kollins SH, Lopez FA, Vince BD, . Psychomotor functioning and alertness with guanfacine extended release in subjects with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2011;21(2):111–20. PMID: 21476931.21476931
Kratochvil CJ, Vaughan BS, Stoner JA, . A double-blind, placebo-controlled study of atomoxetine in young children with ADHD. Pediatrics. 2011;127(4):e862–8. PMID: 21422081.21422081
Kratz O, Studer P, Baack J, . Differential effects of methylphenidate and atomoxetine on attentional processes in children with ADHD: an event-related potential study using the Attention Network Test. Prog Neuropsychopharmacol Biol Psychiatry. 2012;37(1):81–9. PMID: 22227291.22227291
Kray J, Karbach J, Haenig S, . Can task-switching training enhance executive control functioning in children with attention deficit/-hyperactivity disorder?. Front Hum Neurosci. 2011;5:180. PMID: 22291628.22291628
Kubas HA, Backenson EM, Wilcox G, . The effects of methylphenidate on cognitive function in children with attention-deficit/hyperactivity disorder. Postgrad Med. 2012;124(5):33–48. PMID: 23095424.23095424
Lachaine J, Beauchemin C, Sasane R, . Treatment patterns, adherence, and persistence in ADHD: a Canadian perspective. Postgrad Med. 2012;124(3):139–48. PMID: 22691908.22691908
Lamberti M, Italiano D, Guerriero L, . Evaluation of acute cardiovascular effects of immediate-release methylphenidate in children and adolescents with attention-deficit hyperactivity disorder. Neuropsychiatric Disease and Treatment. 2015;11:1169–1174.26056451
Langberg JM, Epstein JN, Becker SP, . Evaluation of the Homework, Organization, and Planning Skills (HOPS) Intervention for Middle School Students with ADHD as Implemented by School Mental Health Providers. School Psych Rev. 2012;41(3):342–364. PMID: 25355991.25355991
Langberg JM, Vaughn AJ, Williamson P, . Refinement of an Organizational Skills Intervention for Adolescents with ADHD for Implementation by School Mental Health Providers. School Ment Health. 2011;3(3):143–155. PMID: 23599833.23599833
Lanzetta-Valdo BP, Oliveira GAD, Ferreira JTC, . Auditory Processing Assessment in Children with Attention Deficit Hyperactivity Disorder: An Open Study Examining Methylphenidate Effects. International Archives of Otorhinolaryngology. 2015.
Larranaga-Fragoso P, Noval S, Rivero JC, . The effects of methylphenidate on refraction and anterior segment parameters in children with attention deficit hyperactivity disorder. J aapos. 2015;19(4):322–6. PMID: 26235791.26235791
Larson T, Kerekes N, Selinus EN, . Reliability of Autism-Tics, AD/HD, and other Comorbidities (A-TAC) inventory in a test-retest design. Psychol Rep. 2014;114(1):93–103. PMID: 24765712.24765712
Lecendreux M, Konofal E, Cortese S, . A 4-year follow-up of attention-deficit/hyperactivity disorder in a population sample. J Clin Psychiatry. 2015;76(6):712–9. PMID: 26132672.26132672
Lee J, Grizenko N, Bhat V, . Relation between therapeutic response and side effects induced by methylphenidate as observed by parents and teachers of children with ADHD. BMC Psychiatry. 2011;11:70. PMID: 21510895.21510895
Lee MS, Lee SI, Hong SD, . Two different solicitation methods for obtaining information on adverse events associated with methylphenidate in adolescents: a 12-week multicenter, open-label study. J Child Adolesc Psychopharmacol. 2013;23(1):22–7. PMID: 23347125.23347125
Lee SH, Seo WS, Sung HM, . Effect of methylphenidate on sleep parameters in children with ADHD. Psychiatry Investig. 2012;9(4):384–90. PMID: 23251204.23251204
Lee SH, Song DH, Kim BN, . Variability of response time as a predictor of methylphenidate treatment response in korean children with attention deficit hyperactivity disorder. Yonsei Med J. 2009;50(5):650–5. PMID: 19881968.19881968
Levy S, Katusic SK, Colligan RC, . Childhood ADHD and risk for substance dependence in adulthood: a longitudinal, population-based study. PLoS One. 2014;9(8):e105640. PMID: 25162629.25162629
Li L, Yang L, Zhuo CJ, . A randomised controlled trial of combined EEG feedback and methylphenidate therapy for the treatment of ADHD. Swiss Med Wkly. 2013;143:w13838. PMID: 23986461.23986461
Liddle EB, Hollis C, Batty MJ, . Task-related default mode network modulation and inhibitory control in ADHD: effects of motivation and methylphenidate. J Child Psychol Psychiatry. 2011;52(7):761–71. PMID: 21073458.21073458
Liechti MD, Maurizio S, Heinrich H, . First clinical trial of tomographic neurofeedback in attention-deficit/hyperactivity disorder: evaluation of voluntary cortical control. Clin Neurophysiol. 2012;123(10):1989–2005. PMID: 22608481.22608481
Lloyd A, Brett D and Wesnes K. Coherence training in children with attention-deficit hyperactivity disorder: cognitive functions and behavioral changes. Altern Ther Health Med. 2010;16(4):34–42. PMID: 20653294.20653294
Loh PR, Piek JP and Barrett NC. Comorbid ADHD and DCD: examining cognitive functions using the WISC-IV. Res Dev Disabil. 2011;32(4):1260–9. PMID: 21377321.21377321
Looyeh MY, Kamali K and Shafieian R. An exploratory study of the effectiveness of group narrative therapy on the school behavior of girls with attention-deficit/hyperactivity symptoms. Arch Psychiatr Nurs. 2012;26(5):404–10. PMID: 22999036.22999036
Lopez FA, Childress A, Adeyi B, . ADHD Symptom Rebound and Emotional Lability With Lisdexamfetamine Dimesylate in Children Aged 6 to 12 Years. J Atten Disord. 2013. PMID: 23407278.23407278
Lopez FA, Scheckner B and Childress AC. Physician perception of clinical improvement in children with attention-deficit/hyperactivity disorder: a post hoc comparison of lisdexamfetamine dimesylate and mixed amphetamine salts extended release in a crossover analog classroom study. Neuropsychiatr Dis Treat. 2011;7:267–73. PMID: 21654872.21654872
Luman M, Goos V and Oosterlaan J. Instrumental learning in ADHD in a context of reward: intact learning curves and performance improvement with methylphenidate. J Abnorm Child Psychol. 2015;43(4):681–91. PMID: 25212229.25212229
Luman M, Papanikolau A and Oosterlaan J. The Unique and Combined Effects of Reinforcement and Methylphenidate on Temporal Information Processing in Attention-Deficit/Hyperactivity Disorder. J Clin Psychopharmacol. 2015;35(4):414–21. PMID: 26075486.26075486
Lyon GJ, Samar SM, Conelea C, . Testing tic suppression: comparing the effects of dexmethylphenidate to no medication in children and adolescents with attention-deficit/hyperactivity disorder and Tourette’s disorder. J Child Adolesc Psychopharmacol. 2010;20(4):283–9. PMID: 20807066.20807066
Maeir A, Fisher O, Bar-Ilan RT, . Effectiveness of Cognitive-Functional (Cog-Fun) occupational therapy intervention for young children with attention deficit hyperactivity disorder: a controlled study. Am J Occup Ther. 2014;68(3):260–7. PMID: 24797189.24797189
Manos MJ, Caserta DA, Short EJ, . Evaluation of the duration of action and comparative effectiveness of lisdexamfetamine dimesylate and behavioral treatment in youth with ADHD in a quasi-naturalistic setting. Journal of Attention Disorders. 2015;19(7):578–590.22930787
Maric M, van Steensel FJ and Bogels SM. Parental Involvement in CBT for Anxiety-Disordered Youth Revisited: Family CBT Outperforms Child CBT in the Long Term for Children With Comorbid ADHD Symptoms. J Atten Disord. 2015. PMID: 25755259.25755259
Martenyi F, Zavadenko NN, Jarkova NB, . Atomoxetine in children and adolescents with attention-deficit/hyperactivity disorder: a 6-week, randomized, placebo-controlled, double-blind trial in Russia. Eur Child Adolesc Psychiatry. 2010;19(1):57–66. PMID: 19568826.19568826
Marx AM, Ehlis AC, Furdea A, . Near-infrared spectroscopy (NIRS) neurofeedback as a treatment for children with attention deficit hyperactivity disorder (ADHD)-a pilot study. Front Hum Neurosci. 2014;8:1038. PMID: 25610390.25610390
Matos M, Bauermeister JJ and Bernal G. Parent-child interaction therapy for Puerto Rican preschool children with ADHD and behavior problems: a pilot efficacy study. Fam Process. 2009;48(2):232–52. PMID: 19579907.19579907
Matsuura N, Ishitobi M, Arai S, . Distinguishing between autism spectrum disorder and attention deficit hyperactivity disorder by using behavioral checklists, cognitive assessments, and neuropsychological test battery. Asian Journal of Psychiatry. 2014;12:50–57.25440561
Matsuura N, Ishitobi M, Arai S, . Effects of methylphenidate in children with attention deficit hyperactivity disorder: A near-infrared spectroscopy study with CANTAB®. Child and Adolescent Psychiatry and Mental Health. 2014;8.
Maurizio S, Liechti MD, Heinrich H, . Comparing tomographic EEG neurofeedback and EMG biofeedback in children with attention-deficit/hyperactivity disorder. Biol Psychol. 2014;95:31–44. PMID: 24211870.24211870
Mazaheri A, Fassbender C, Coffey-Corina S, . Differential oscillatory electroencephalogram between attention-deficit/hyperactivity disorder subtypes and typically developing adolescents. Biological Psychiatry. 2014;76(5):422–429.24120092
Mazzone L, Postorino V, Reale L, . Self-esteem evaluation in children and adolescents suffering from ADHD. Clin Pract Epidemiol Ment Health. 2013;9:96–102. PMID: 23878614.23878614
McAfee AT, Landon J, Jones M, . A cohort study of the risk of seizures in a pediatric population treated with atomoxetine or stimulant medications. Pharmacoepidemiol Drug Saf. 2013;22(4):386–93. PMID: 23280590.23280590
McCracken JT, Badashova KK, Posey DJ, . Positive effects of methylphenidate on hyperactivity are moderated by monoaminergic gene variants in children with autism spectrum disorders. Pharmacogenomics J. 2014;14(3):295–302. PMID: 23856854.23856854
McGough JJ, Greenbaum M, Adeyi B, . Sex subgroup analysis of treatment response to lisdexamfetamine dimesylate in children aged 6 to 12 years with attention-deficit/hyperactivity disorder. Journal of Clinical Psychopharmacology. 2012;32(1):138–140. PMID: 2012-02030-029.22217951
McGough JJ, Loo SK, Sturm A, . An eight-week, open-trial, pilot feasibility study of trigeminal nerve stimulation in youth with attention-deficit/hyperactivity disorder. Brain Stimul. 2015;8(2):299–304. PMID: 25533244.25533244
Medina JA, Netto TL, Muszkat M, . Exercise impact on sustained attention of ADHD children, methylphenidate effects. Atten Defic Hyperact Disord. 2010;2(1):49–58. PMID: 21432590.21432590
Meguid N, Effat S, Hussien H, . Role of plasma fatty acids in Egyptian children with attention deficit hyperactivity disorder. International Journal of Pharmaceutical and Clinical Research. 2016;8(7):671–675.
Meisel V, Servera M, Garcia-Banda G, . Neurofeedback and standard pharmacological intervention in ADHD: a randomized controlled trial with six-month follow-up. Biol Psychol. 2013;94(1):12–21. PMID: 23665196.23665196
Meisel V, Servera M, Garcia-Banda G, . Reprint of “Neurofeedback and standard pharmacological intervention in ADHD: a randomized controlled trial with six-month follow-up”. Biol Psychol. 2014;95:116–25. PMID: 24055220.24055220
Menezes A, Dias NM, Trevisan BT, . Intervention for executive functions in attention deficit and hyperactivity disorder. Arq Neuropsiquiatr. 2015;73(3):227–36. PMID: 25807129.25807129
Michelini G, Kitsune GL, Cheung CH, . Attention-Deficit/Hyperactivity Disorder Remission Is Linked to Better Neurophysiological Error Detection and Attention-Vigilance Processes. Biol Psychiatry. 2016. PMID: 27591125.27591125
Mikami AY, Cox DJ, Davis MT, . Sex differences in effectiveness of extended-release stimulant medication among adolescents with attention-deficit/hyperactivity disorder. J Clin Psychol Med Settings. 2009;16(3):233–42. PMID: 19418208.19418208
Mikami AY, Griggs MS, Lerner MD, . A randomized trial of a classroom intervention to increase peers’ social inclusion of children with attention-deficit/hyperactivity disorder. J Consult Clin Psychol. 2013;81(1):100–12. PMID: 22866680.22866680
Miranda A, Presentacion MJ, Siegenthaler R, . Effects of a psychosocial intervention on the executive functioning in children with ADHD. J Learn Disabil. 2013;46(4):363–76. PMID: 22064952.22064952
Mitchell TB, Cooley JL, Evans SC, . The moderating effect of physical activity on the association between ADHD symptoms and peer victimization in middle childhood. Child Psychiatry and Human Development. 2016;47(6):871–882.26710759
Miyahara M, Healey DM and Halperin JM. One-week temporal stability of hyperactivity in preschoolers with ADHD during psychometric assessment. Psychiatry Clin Neurosci. 2014;68(2):120–6. PMID: 24552632.24552632
Mohammadi MR, Hafezi P, Galeiha A, . Buspirone versus methylphenidate in the treatment of children with attention- deficit/hyperactivity disorder: randomized double-blind study. Acta Med Iran. 2012;50(11):723–8. PMID: 23292622.23292622
Mohammadi MR, Kazemi MR, Zia E, . Amantadine versus methylphenidate in children and adolescents with attention deficit/hyperactivity disorder: a randomized, double-blind trial. Hum Psychopharmacol. 2010;25(7–8):560–5. PMID: 21312290.21312290
Mohammadi MR, Mohammadzadeh S and Akhondzadeh S. Memantine versus methylphenidate in children and adolescents with attention deficit hyperactivity disorder: A double-blind, randomized clinical trial. Iranian Journal of Psychiatry. 2015;10(2):106–114.26884787
Mohammadi MR, Soleimani AA, Ahmadi N, . A Comparison of Effectiveness of Parent Behavioral Management Training and Methylphenidate on Reduction of Symptomsof Attention Deficit Hyperactivity Disorder. Acta Med Iran. 2016;54(8):503–509. PMID: 27701720.27701720
Mohammadi MR, Soleimani AA, Farahmand Z, . A comparison of effectiveness of regulation of working memory function and methylphenidate on remediation of attention deficit hyperactivity disorder (ADHD). Iran J Psychiatry. 2014;9(1):25–30. PMID: 25561945.25561945
Montoya A, Hervas A, Cardo E, . Evaluation of atomoxetine for first-line treatment of newly diagnosed, treatment-naive children and adolescents with attention deficit/hyperactivity disorder. Curr Med Res Opin. 2009;25(11):2745–54. PMID: 19785510.19785510
Moreno A, Duno L, Hoekzema E, . Striatal volume deficits in children with ADHD who present a poor response to methylphenidate. Eur Child Adolesc Psychiatry. 2014;23(9):805–12. PMID: 24395136.24395136
Morgan PL, Li H, Cook M, . Which Kindergarten Children Are at Greatest Risk for Attention-Deficit/Hyperactivity and Conduct Disorder Symptomatology as Adolescents?. Sch Psychol Q. 2015. PMID: 26192391.26192391
Moshe K, Karni A and Tirosh E. Anxiety and methylphenidate in attention deficit hyperactivity disorder: a double-blind placebo-drug trial. Atten Defic Hyperact Disord. 2012;4(3):153–8. PMID: 22622628.22622628
Munkvold LH, Manger T and Lundervold AJ. Conners’ continuous performance test (CCPT-II) in children with ADHD, ODD, or a combined ADHD/ODD diagnosis. Child Neuropsychol. 2014;20(1):106–26. PMID: 23244393.23244393
Munz MT, Prehn-Kristensen A, Thielking F, . Slow oscillating transcranial direct current stimulation during non-rapid eye movement sleep improves behavioral inhibition in attention-deficit/hyperactivity disorder. Front Cell Neurosci. 2015;9:307. PMID: 26321911.26321911
Murray DW, Childress A, Giblin J, . Effects of OROS methylphenidate on academic, behavioral, and cognitive tasks in children 9 to 12 years of age with attention-deficit/hyperactivity disorder. Clin Pediatr (Phila). 2011;50(4):308–20. PMID: 21436147.21436147
Murrell AR, Steinberg DS, Connally ML, . Acting out to ACTing on: A preliminary investigation in youth with ADHD and co-morbid disorders. Journal of Child and Family Studies. 2015;24(7):2174–2181.
Nagashima M, Monden Y, Dan I, . Neuropharmacological effect of atomoxetine on attention network in children with attention deficit hyperactivity disorder during oddball paradigms as assessed using functional near-infrared spectroscopy. Neurophotonics. 2014;1(2):025007. PMID: 26157979.26157979
Nagashima M, Monden Y, Dan I, . Neuropharmacological effect of methylphenidate on attention network in children with attention deficit hyperactivity disorder during oddball paradigms as assessed using functional near-infrared spectroscopy. Neurophotonics. 2014;1(1):015001. PMID: 26157971.26157971
Nagy P, Hage A, Coghill DR, . Functional outcomes from a head-to-head, randomized, double-blind trial of lisdexamfetamine dimesylate and atomoxetine in children and adolescents with attention-deficit/hyperactivity disorder and an inadequate response to methylphenidate. Eur Child Adolesc Psychiatry. 2015. PMID: 25999292.25999292
Neguţ A, Jurma AM and David D. Virtual-reality-based attention assessment of ADHD: ClinicaVR: Classroom-CPT versus a traditional continuous performance test. Child Neuropsychology. 2016:1–21.
Newcorn JH and Donnelly C. Cardiovascular safety of medication treatments for attention-deficit/hyperactivity disorder. Mt Sinai J Med. 2009;76(2):198–203. PMID: 19306385.19306385
Newcorn JH, Stein MA and Cooper KM. Dose-response characteristics in adolescents with attention-deficit/hyperactivity disorder treated with OROS methylphenidate in a 4-week, open-label, dose-titration study. J Child Adolesc Psychopharmacol. 2010;20(3):187–96. PMID: 20578931.20578931
Newcorn JH, Stein MA, Childress AC, . Randomized, double-blind trial of guanfacine extended release in children with attention-deficit/hyperactivity disorder: morning or evening administration. J Am Acad Child Adolesc Psychiatry. 2013;52(9):921–30. PMID: 23972694.23972694
Newcorn JH, Sutton VK, Weiss MD, . Clinical responses to atomoxetine in attention-deficit/hyperactivity disorder: the Integrated Data Exploratory Analysis (IDEA) study. J Am Acad Child Adolesc Psychiatry. 2009;48(5):511–8. PMID: 19318988.19318988
Niederhofer H. Agomelatine treatment with adolescents with ADHD. J Atten Disord. 2012;16(6):530–2. PMID: 22668524.22668524
Niederhofer H. Treating ADHD with agomelatine. J Atten Disord. 2012;16(4):346–8. PMID: 22491963.22491963
Ogrim G and Hestad KA. Effects of neurofeedback versus stimulant medication in attention-deficit/hyperactivity disorder: a randomized pilot study. J Child Adolesc Psychopharmacol. 2013;23(7):448–57. PMID: 23808786.23808786
Ogrim G, Hestad KA, Brunner JF, . Predicting acute side effects of stimulant medication in pediatric attention deficit/hyperactivity disorder: data from quantitative electroencephalography, event-related potentials, and a continuous-performance test. Neuropsychiatr Dis Treat. 2013;9:1301–9. PMID: 24043939.24043939
O’Mahony N, Florentino-Liano B, Carballo JJ, . Objective diagnosis of ADHD using IMUs. Med Eng Phys. 2014;36(7):922–6. PMID: 24657100.24657100
O’Neill S, Schneiderman RL, Rajendran K, . Reliable ratings or reading tea leaves: can parent, teacher, and clinician behavioral ratings of preschoolers predict ADHD at age six?. J Abnorm Child Psychol. 2014;42(4):623–34. PMID: 24085388.24085388
Owens J, Weiss M, Nordbrock E, . Effect of Aptensio XR (Methylphenidate HCl Extended-Release) Capsules on Sleep in Children with Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2016. PMID: 27754700.27754700
Ozbaran B, Kose S, Yuzuguldu O, . Combined methylphenidate and atomoxetine pharmacotherapy in attention deficit hyperactivity disorder. World Journal of Biological Psychiatry. 2015;16(8):619–624.26223958
Palma SMM, Natale ACMP and Calil HM. A 4-year follow-up study of attention-deficit hyperactivity symptoms, comorbidities, and psychostimulant use in a Brazilian sample of children and adolescents with attention-deficit/hyperactivity disorder. Frontiers in Psychiatry. 2015;6(OCT).
Park P, Caballero J and Omidian H. Use of serotonin norepinephrine reuptake inhibitors in the treatment of attention-deficit hyperactivity disorder in pediatrics. Ann Pharmacother. 2014;48(1):86–92. PMID: 24259607.24259607
Park S, Kim BN, Cho SC, . Baseline severity of parent-perceived inattentiveness is predictive of the difference between subjective and objective methylphenidate responses in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2013;23(6):410–4. PMID: 23952188.23952188
Park S, Kim BN, Cho SC, . The metabotropic glutamate receptor subtype 7 rs3792452 polymorphism is associated with the response to methylphenidate in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2014;24(4):223–7. PMID: 24815731.24815731
Park S, Kim B-N, Kim J-W, . Neurotrophin 3 genotype and emotional adverse effects of osmotic-release oral system methylphenidate (OROS-MPH) in children with attention-deficit/hyperactivity disorder. Journal of Psychopharmacology. 2014;28(3):220–226. PMID: 2014-10977-004.23471121
Park S, Kim JW, Kim BN, . Catechol-O-methyltransferase Val158-Met polymorphism and a response of hyperactive-impulsive symptoms to methylphenidate: A replication study from South Korea. J Psychopharmacol. 2014;28(7):671–676. PMID: 24763183.24763183
Pelham WE, Burrows-MacLean L, Gnagy EM, . A dose-ranging study of behavioral and pharmacological treatment in social settings for children with ADHD. J Abnorm Child Psychol. 2014;42(6):1019–31. PMID: 24429997.24429997
Pelham WE, Jr, Gnagy EM, Sibley MH, . Attributions and Perception of Methylphenidate Effects in Adolescents With ADHD. J Atten Disord. 2013. PMID: 23893533.23893533
Pelsser LM, Frankena K, Toorman J, . A randomised controlled trial into the effects of food on ADHD. Eur Child Adolesc Psychiatry. 2009;18(1):12–9. PMID: 18431534.18431534
Pelsser LM, van Steijn DJ, Frankena K, . A randomized controlled pilot study into the effects of a restricted elimination diet on family structure in families with ADHD and ODD. Child and Adolescent Mental Health. 2013;18(1):39–45.
Percinel I, Yazici KU and Ustundag B. Iron Deficiency Parameters in Children and Adolescents with Attention-Deficit/Hyperactivity Disorder. Child Psychiatry Hum Dev. 2015. PMID: 26092605.26092605
Perreau-Linck E, Lessard N, Lévesque J, . Effects of neurofeed back training on inhibitory capacities in ADHD children: A single-blind, randomized, placebo-controlled study. Journal of Neurotherapy. 2010;14(3):229–242.
Peyre H, Speranza M, Cortese S, . Do ADHD children with and without Child Behavior Checklist–Dysregulation Profile have different clinical characteristics, cognitive features, and treatment outcomes?. Journal of Attention Disorders. 2015;19(1):63–71.22837549
Pierce D, Katic A, Buckwalter M, . Single- and multiple-dose pharmacokinetics of methylphenidate administered as methylphenidate transdermal system or osmotic-release oral system methylphenidate to children and adolescents with attention deficit hyperactivity disorder. J Clin Psychopharmacol. 2010;30(5):554–64. PMID: 20814325.20814325
Pontifex MB, Saliba BJ, Raine LB, . Exercise improves behavioral, neurocognitive, and scholastic performance in children with attention-deficit/hyperactivity disorder. J Pediatr. 2013;162(3):543–51. PMID: 23084704.23084704
Posner J, Siciliano F, Wang Z, . A multimodal MRI study of the hippocampus in medication-naive children with ADHD: what connects ADHD and depression?. Psychiatry Res. 2014;224(2):112–8. PMID: 25220159.25220159
Posserud MB, Ullebø AK, Plessen KJ, . Influence of assessment instrument on ADHD diagnosis. European Child and Adolescent Psychiatry. 2014;23(4):197–205.23824470
Power TJ, Mautone JA, Marshall SA, . Feasibility and potential effectiveness of integrated services for children with ADHD in urban primary care practices. Clinical Practice in Pediatric Psychology. 2014;2(4):412–426.
Prehn-Kristensen A, Krauel K, Hinrichs H, . Methylphenidate does not improve interference control during a working memory task in young patients with attention-deficit hyperactivity disorder. Brain Research. 2011;1388:56–68.21385569
Prehn-Kristensen A, Munz M, Goder R, . Transcranial oscillatory direct current stimulation during sleep improves declarative memory consolidation in children with attention-deficit/hyperactivity disorder to a level comparable to healthy controls. Brain Stimul. 2014;7(6):793–9. PMID: 25153776.25153776
Pringsheim T, Hirsch L, Gardner D, . The pharmacological management of oppositional behaviour, conduct problems, and Aggression in children and adolescents with Attention-deficit hyperactivity disorder, oppositional defiant disorder, and conduct disorder: A systematic review and meta-analysis. Part 2: Antipsychotics and traditional mood stabilizers. Canadian Journal of Psychiatry. 2015;60(2):52–61.25886656
Punja S, Nikles CJ, Senior H, . Melatonin in Youth: N-of-1 trials in a stimulant-treated ADHD Population (MYNAP): Study protocol for a randomized controlled trial. Trials. 2016;17(1).
Quantitative electroencephalography as a diagnostic aid for attention-deficit/hyperactivity disorder in children. Technol Eval Cent Assess Program Exec Summ. 2014;29(1):1–6. PMID: 25577822.25577822
Rajender G, Malhotra S, Bhatia MS, . Efficacy of cognitive retraining techniques in children with attention deficit hyperactivity disorder. German Journal of Psychiatry. 2011;14(2):55–60.
Raman SR, Marshall SW, Haynes K, . Stimulant treatment and injury among children with attention deficit hyperactivity disorder: an application of the self-controlled case series study design. Inj Prev. 2013;19(3):164–70. PMID: 23143347.23143347
Ramtvedt BE, Aabech HS and Sundet K. Minimizing adverse events while maintaining clinical improvement in a pediatric attention-deficit/hyperactivity disorder crossover trial with dextroamphetamine and methylphenidate. J Child Adolesc Psychopharmacol. 2014;24(3):130–9. PMID: 24666268.24666268
Ramtvedt BE, Roinas E, Aabech HS, . Clinical gains from including both dextroamphetamine and methylphenidate in stimulant trials. J Child Adolesc Psychopharmacol. 2013;23(9):597–604. PMID: 23659360.23659360
Re AM, Capodieci A and Cornoldi C. Effect of training focused on executive functions (attention, inhibition, and working memory) in preschoolers exhibiting ADHD symptoms. Frontiers in Psychology. 2015;6.
Rheims S, Herbillon V, Villeneuve N, . ADHD in childhood epilepsy: Clinical determinants of severity and of the response to methylphenidate. Epilepsia. 2016;57(7):1069–77. PMID: 27237724.27237724
Richardson M, Moore DA, Gwernan-Jones R, . Non-pharmacological interventions for attention-deficit/hyperactivity disorder (ADHD) delivered in school settings: systematic reviews of quantitative and qualitative research. Health Technol Assess. 2015;19(45):1–470. PMID: 26129788.26129788
Riggs PD, Winhusen T, Davies RD, . Randomized controlled trial of osmotic-release methylphenidate with cognitive-behavioral therapy in adolescents with attention-deficit/hyperactivity disorder and substance use disorders. J Am Acad Child Adolesc Psychiatry. 2011;50(9):903–14. PMID: 21871372.21871372
Rimvall MK, Elberling H, Rask CU, . Predicting ADHD in school age when using the Strengths and Difficulties Questionnaire in preschool age: a longitudinal general population study, CCC2000. Eur Child Adolesc Psychiatry. 2014;23(11):1051–60. PMID: 24737124.24737124
Robb AS, Findling RL, Childress AC, . Efficacy, Safety, and Tolerability of a Novel Methylphenidate Extended-Release Oral Suspension (MEROS) in ADHD. J Atten Disord. 2014. PMID: 24874348.24874348
Rodriguez C, Gonzalez-Castro P, Cueli M, . Attention Deficit/Hyperactivity Disorder (ADHD) Diagnosis: An Activation-Executive Model. Front Psychol. 2016;7:1406. PMID: 27708600.27708600
Rommel AS, Lichtenstein P, Rydell M, . Is Physical Activity Causally Associated With Symptoms of Attention-Deficit/Hyperactivity Disorder?. J Am Acad Child Adolesc Psychiatry. 2015;54(7):565–70. PMID: 26088661.26088661
Rosch KS, Fosco WD, Pelham WE, Jr, . Reinforcement and Stimulant Medication Ameliorate Deficient Response Inhibition in Children with Attention-Deficit/Hyperactivity Disorder. J Abnorm Child Psychol. 2015. PMID: 25985978.25985978
Rosenberg L, Maeir A, Yochman A, . Effectiveness of a cognitive-functional group intervention among preschoolers with attention deficit hyperactivity disorder: A pilot study. American Journal of Occupational Therapy. 2015;69(3):p1–p8.
Rubia K, Halari R, Cubillo A, . Methylphenidate normalises activation and functional connectivity deficits in attention and motivation networks in medication-naive children with ADHD during a rewarded continuous performance task. Neuropharmacology. 2009;57(7–8):640–52. PMID: 19715709.19715709
Rubia K, Halari R, Cubillo A, . Methylphenidate normalizes fronto-striatal underactivation during interference inhibition in medication-naive boys with attention-deficit hyperactivity disorder. Neuropsychopharmacology. 2011;36(8):1575–86. PMID: 21451498.21451498
Ruggiero S, Rafaniello C, Bravaccio C, . Safety of attention-deficit/hyperactivity disorder medications in children: an intensive pharmacosurveillance monitoring study. J Child Adolesc Psychopharmacol. 2012;22(6):415–22. PMID: 23234585.23234585
Rugino TA. Effect on Primary Sleep Disorders When Children With ADHD Are Administered Guanfacine Extended Release. J Atten Disord. 2014. PMID: 25376194.25376194
Sallee FR, Kollins SH and Wigal TL. Efficacy of guanfacine extended release in the treatment of combined and inattentive only subtypes of attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2012;22(3):206–14. PMID: 22612526.22612526
Sallee FR, McGough J, Wigal T, . Guanfacine extended release in children and adolescents with attention-deficit/hyperactivity disorder: a placebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2009;48(2):155–65. PMID: 19106767.19106767
Sander C, Arns M, Olbrich S, . EEG-vigilance and response to stimulants in paediatric patients with attention deficit/hyperactivity disorder. Clin Neurophysiol. 2010;121(9):1511–8. PMID: 20382071.20382071
Sanefuji M, Yamashita H, Torisu H, . Altered strategy in short-term memory for pictures in children with attention-deficit/hyperactivity disorder: a near-infrared spectroscopy study. Psychiatry Res. 2014;223(1):37–42. PMID: 24840133.24840133
Santisteban JA, Stein MA, Bergmame L, . Effect of extended-release dexmethylphenidate and mixed amphetamine salts on sleep: a double-blind, randomized, crossover study in youth with attention-deficit hyperactivity disorder. CNS Drugs. 2014;28(9):825–33. PMID: 25056567.25056567
Sasaki T, Hashimoto K, Tachibana M, . Tipepidine in children with attention deficit/hyperactivity disorder: a 4-week, open-label, preliminary study. Neuropsychiatr Dis Treat. 2014;10:147–51. PMID: 24493927.24493927
Schawo S, van der Kolk A, Bouwmans C, . Probabilistic Markov Model Estimating Cost Effectiveness of Methylphenidate Osmotic-Release Oral System Versus Immediate-Release Methylphenidate in Children and Adolescents: Which Information is Needed?. Pharmacoeconomics. 2015;33(5):489–509. PMID: 25715975.25715975
Schelleman H, Bilker WB, Strom BL, . Cardiovascular events and death in children exposed and unexposed to ADHD agents. Pediatrics. 2011;127(6):1102–10. PMID: 21576311.21576311
Schlochtermeier L, Stoy M, Schlagenhauf F, . Childhood methylphenidate treatment of ADHD and response to affective stimuli. Eur Neuropsychopharmacol. 2011;21(8):646–54. PMID: 20570115.20570115
Schuck SE, Emmerson NA, Fine AH, . Canine-assisted therapy for children with ADHD: preliminary findings from the positive assertive cooperative kids study. J Atten Disord. 2015;19(2):125–37. PMID: 24062278.24062278
Schulz E, Fleischhaker C, Hennighausen K, . A double-blind, randomized, placebo/active controlled crossover evaluation of the efficacy and safety of Ritalin (R) LA in children with attention-deficit/hyperactivity disorder in a laboratory classroom setting. J Child Adolesc Psychopharmacol. 2010;20(5):377–85. PMID: 20973708.20973708
Schulz E, Fleischhaker C, Hennighausen K, . A randomized, rater-blinded, crossover study comparing the clinical efficacy of Ritalin((R)) LA (methylphenidate) treatment in children with attention-deficit hyperactivity disorder under different breakfast conditions over 2 weeks. Atten Defic Hyperact Disord. 2010;2(3):133–8. PMID: 21432599.21432599
Schwartz BS, Bailey-Davis L, Bandeen-Roche K, . Attention deficit disorder, stimulant use, and childhood body mass index trajectory. Pediatrics. 2014;133(4):668–76. PMID: 24639278.24639278
Schwenck C and Freitag CM. Differentiation between attention-deficit/hyperactivity disorder and autism spectrum disorder by the social communication questionnaire. Atten Defic Hyperact Disord. 2014;6(3):221–9. PMID: 24966019.24966019
Sciberras E, Bisset M, Hazell P, . Health-related impairments in young children with ADHD: A community-based study. Child: Care, Health and Development. 2016;42(5):709–717.
Sciberras E, Lycett K, Efron D, . Anxiety in children with attention-deficit/hyperactivity disorder. Pediatrics. 2014;133(5):801–8. PMID: 24753534.24753534
Sciberras E, Mulraney M, Anderson V, . Managing Anxiety in Children With ADHD Using Cognitive-Behavioral Therapy: A Pilot Randomized Controlled Trial. J Atten Disord. 2015. PMID: 25939582.25939582
Seeley JR, Small JW, Walker HM, . Efficacy of the First Step to Success intervention for students with attention-deficit/hyperactivity disorder. School Mental Health. 2009;1(1):37–48.
Seida JC, Schouten JR, Mousavi SS, . AHRQ Comparative Effectiveness Reviews. 2012. PMID: 22439156.22439156
Setyawan J, Yang H, Cheng D, . Developing a Risk Score to Guide Individualized Treatment Selection in Attention Deficit/Hyperactivity Disorder. Value Health. 2015;18(6):824–31. PMID: 26409610.26409610
Shahani SA, Evans WN, Mayman GA, . Attention deficit hyperactivity disorder screening electrocardiograms: a community-based perspective. Pediatr Cardiol. 2014;35(3):485–9. PMID: 24141829.24141829
Shang CY and Gau SS. Improving visual memory, attention, and school function with atomoxetine in boys with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2012;22(5):353–63. PMID: 23083022.23083022
Shang CY, Pan YL, Lin HY, . An Open-Label, Randomized Trial of Methylphenidate and Atomoxetine Treatment in Children with Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2015;25(7):566–73. PMID: 26222447.26222447
Shaywitz S, Shaywitz B, Wietecha L, . Effect of Atomoxetine Treatment on Reading and Phonological Skills in Children with Dyslexia or Attention-Deficit/Hyperactivity Disorder and Comorbid Dyslexia in a Randomized, Placebo-Controlled Trial. J Child Adolesc Psychopharmacol. 2016. PMID: 27410907.27410907
Shemmassian SK and Lee SS. Comparing four methods of integrating parent and teacher symptom ratings of attention-deficit/hyperactivity disorder (ADHD). Journal of Psychopathology and Behavioral Assessment. 2012;34(1):1–10.
Shin MS, Jeon H, Kim M, . Effects of smart-tablet-based neurofeedback training on cognitive function in children with attention problems. Journal of Child Neurology. 2015;31(6):750–760.26681772
Sibley MH, Altszuler AR, Morrow AS, . Mapping the academic problem behaviors of adolescents with ADHD. Sch Psychol Q. 2014;29(4):422–37. PMID: 24933215.24933215
Sibley MH, Pelham Jr WE, Derefinko KJ, . A pilot trial of supporting teens’ academic needs daily (STAND): A parent-adolescent collaborative intervention for ADHD. Journal of Psychopathology and Behavioral Assessment. 2013;35(4):436–449.
Sibley MH, Pelham WE, Evans SW, . An Evaluation of a Summer Treatment Program for Adolescents With ADHD. Cognitive and Behavioral Practice. 2011;18(4):530–544.
Sigi Hale T, Wiley JF, Smalley SL, . A parietal biomarker for ADHD liability: As predicted by the distributed effects perspective model of ADHD. Frontiers in Psychiatry. 2015;6(MAY).
Signorovitch J, Erder MH, Xie J, . Comparative effectiveness research using matching-adjusted indirect comparison: an application to treatment with guanfacine extended release or atomoxetine in children with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder. Pharmacoepidemiol Drug Saf. 2012;21(Suppl 2):130–7. PMID: 22552988.22552988
Sikirica V, Findling RL, Signorovitch J, . Comparative efficacy of guanfacine extended release versus atomoxetine for the treatment of attention-deficit/hyperactivity disorder in children and adolescents: applying matching-adjusted indirect comparison methodology. CNS Drugs. 2013;27(11):943–53. PMID: 23975660.23975660
Sikirica V, Haim Erder M, Xie J, . Cost effectiveness of guanfacine extended release as an adjunctive therapy to a stimulant compared with stimulant monotherapy for the treatment of attention-deficit hyperactivity disorder in children and adolescents. Pharmacoeconomics. 2012;30(8):e1–15. PMID: 22788263.22788263
Silk TJ, Newman DP, Eramudugolla R, . Influence of methylphenidate on spatial attention asymmetry in adolescents with attention deficit hyperactivity disorder (ADHD): preliminary findings. Neuropsychologia. 2014;56:178–83. PMID: 24486422.24486422
Silva RR, Brams M, McCague K, . Extended-release dexmethylphenidate 30 mg/d versus 20 mg/d: duration of attention, behavior, and performance benefits in children with attention-deficit/hyperactivity disorder. Clin Neuropharmacol. 2013;36(4):117–21. PMID: 23860345.23860345
Simonoff E, Taylor E, Baird G, . Randomized controlled double-blind trial of optimal dose methylphenidate in children and adolescents with severe attention deficit hyperactivity disorder and intellectual disability. J Child Psychol Psychiatry. 2013;54(5):527–35. PMID: 22676856.22676856
Siu AFY and Zhou Y. Behavioral Assessment of the Dysexecutive Syndrome for Children: An examination of clinical utility for children with attention-deficit hyperactivity disorder (ADHD). Journal of Child Neurology. 2014;29(5):608–616.24453147
Sjowall D, Bohlin G, Rydell AM, . Neuropsychological deficits in preschool as predictors of ADHD symptoms and academic achievement in late adolescence. Child Neuropsychol. 2015:1–18. PMID: 26212755.26212755
Skogan AH, Zeiner P, Egeland J, . Parent ratings of executive function in young preschool children with symptoms of attention-deficit/-hyperactivity disorder. Behav Brain Funct. 2015;11:16. PMID: 25889243.25889243
Slama H, Fery P, Verheulpen D, . Cognitive Improvement of Attention and Inhibition in the Late Afternoon in Children With Attention-Deficit Hyperactivity Disorder (ADHD) Treated With Osmotic-Release Oral System Methylphenidate. J Child Neurol. 2015;30(8):1000–9. PMID: 25296928.25296928
Smith A, Cubillo A, Barrett N, . Neurofunctional effects of methylphenidate and atomoxetine in boys with attention-deficit/hyperactivity disorder during time discrimination. Biol Psychiatry. 2013;74(8):615–22. PMID: 23731741.23731741
Snircova E, Hrtanek I, Kulhan T, . Atomoxetine and methylphenidate treatment in ADHD. Acta Medica Martiniana. 2015;15(1):20–26.
Socanski D, Aurlien D, Herigstad A, . Attention deficit/hyperactivity disorder and interictal epileptiform discharges: it is safe to use methylphenidate?. Seizure. 2015;25:80–3. PMID: 25645642.25645642
Solanto M, Newcorn J, Vail L, . Stimulant drug response in the predominantly inattentive and combined subtypes of attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(6):663–71. PMID: 20035584.20035584
Song DH, Choi S, Joung YS, . Titrating Optimal Dose of Osmotic-Controlled Release Oral Delivery (OROS)-Methylphenidate and Its Efficacy and Safety in Korean Children with ADHD: A Multisite Open Labeled Study. Psychiatry Investig. 2012;9(3):257–62. PMID: 22993525.22993525
Sonnby K, Skordas K, Olofsdotter S, . Validation of the World Health Organization Adult ADHD Self-Report Scale for adolescents. Nord J Psychiatry. 2015;69(3):216–23. PMID: 25348323.25348323
Soutullo C, Banaschewski T, Lecendreux M, . A post hoc comparison of the effects of lisdexamfetamine dimesylate and osmotic-release oral system methylphenidate on symptoms of attention-deficit hyperactivity disorder in children and adolescents. CNS Drugs. 2013;27(9):743–51. PMID: 23801529.23801529
Spencer TJ, Greenbaum M, Ginsberg LD, . Safety and effectiveness of coadministration of guanfacine extended release and psychostimulants in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(5):501–10. PMID: 19877974.19877974
Sprich SE, Burbridge J, Lerner JA, . Cognitive-behavioral therapy for ADHD in adolescents: Clinical considerations and a case series. Cognitive and Behavioral Practice. 2015;22(2):116–126.27616874
Sprich SE, Safren SA, Finkelstein D, . A randomized controlled trial of cognitive behavioral therapy for ADHD in medication-treated adolescents. J Child Psychol Psychiatry. 2016. PMID: 26990084.26990084
Steenhuis MP, Serra M, Minderaa RB, . An Internet version of the Diagnostic Interview Schedule for Children (DISC-IV): correspondence of the ADHD section with the paper-and-pencil version. Psychol Assess. 2009;21(2):231–4. PMID: 19485678.19485678
Stein MA, Sikirica V, Weiss MD, . Does Guanfacine Extended Release Impact Functional Impairment in Children with Attention-Deficit/Hyperactivity Disorder? Results from a Randomized Controlled Trial. CNS Drugs. 2015. PMID: 26547425.26547425
Stein MA, Waldman I, Newcorn J, . Dopamine transporter genotype and stimulant dose-response in youth with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2014;24(5):238–44. PMID: 24813374.24813374
Stein MA, Waldman ID, Charney E, . Dose effects and comparative effectiveness of extended release dexmethylphenidate and mixed amphetamine salts. J Child Adolesc Psychopharmacol. 2011;21(6):581–8. PMID: 22136094.22136094
Steiner NJ, Sheldrick RC, Gotthelf D, . Computer-based attention training in the schools for children with attention deficit/hyperactivity disorder: a preliminary trial. Clin Pediatr (Phila). 2011;50(7):615–22. PMID: 21561933.21561933
Steinhausen HC and Bisgaard C. Substance use disorders in association with attention-deficit/hyperactivity disorder, co-morbid mental disorders, and medication in a nationwide sample. Eur Neuropsychopharmacol. 2014;24(2):232–41. PMID: 24314850.24314850
Storebo OJ, Skoog M, Rasmussen PD, . Attachment Competences in Children With ADHD During the Social-Skills Training and Attachment (SOSTRA) Randomized Clinical Trial. J Atten Disord. 2015;19(10):865–71. PMID: 24532801.24532801
Strand MT, Hawk LW, Jr., Bubnik M, . Improving working memory in children with attention-deficit/hyperactivity disorder: the separate and combined effects of incentives and stimulant medication. J Abnorm Child Psychol. 2012;40(7):1193–207. PMID: 22477205.22477205
Su Y, Yang L, Stein MA, . Osmotic Release Oral System Methylphenidate Versus Atomoxetine for the Treatment of Attention-Deficit/Hyperactivity Disorder in Chinese Youth: 8-Week Comparative Efficacy and 1-Year Follow-Up. J Child Adolesc Psychopharmacol. 2016;26(4):362–71. PMID: 26779845.26779845
Svanborg P, Thernlund G, Gustafsson PA, . Atomoxetine improves patient and family coping in attention deficit/hyperactivity disorder: a randomized, double-blind, placebo-controlled study in Swedish children and adolescents. Eur Child Adolesc Psychiatry. 2009;18(12):725–35. PMID: 19466476.19466476
Svanborg P, Thernlund G, Gustafsson PA, . Efficacy and safety of atomoxetine as add-on to psychoeducation in the treatment of attention deficit/hyperactivity disorder: a randomized, double-blind, placebo-controlled study in stimulant-naive Swedish children and adolescents. Eur Child Adolesc Psychiatry. 2009;18(4):240–9. PMID: 19156355.19156355
Symmes A, Winters KC, Fahnhorst T, . The Association Between Attention-Deficit Hyperactivity Disorder and Nicotine Use Among Adolescents and Young Adults. J Child Adolesc Subst Abuse. 2015;24(1):37–45. PMID: 25632218.25632218
Takahashi J, Yasumura A, Nakagawa E, . Changes in negative and positive EEG shifts during slow cortical potential training in children with attention-deficit/hyperactivity disorder: A preliminary investigation. NeuroReport: For Rapid Communication of Neuroscience Research. 2014;25(8):618–624. PMID: 2014-17071-013.
Takahashi M, Takita Y, Yamazaki K, . A randomized, double-blind, placebo-controlled study of atomoxetine in Japanese children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(4):341–50. PMID: 19702486.19702486
Ter-Stepanian M, Grizenko N, Zappitelli M, . Clinical response to methylphenidate in children diagnosed with attention-deficit hyperactivity disorder and comorbid psychiatric disorders. Can J Psychiatry. 2010;55(5):305–12. PMID: 20482957.20482957
Teuscher NS, Adjei A, Findling RL, . Population pharmacokinetics of methylphenidate hydrochloride extended-release multiple-layer beads in pediatric subjects with attention deficit hyperactivity disorder. Drug Des Devel Ther. 2015;9:2767–75. PMID: 26060393.26060393
Thompson MJ, Laver-Bradbury C, Ayres M, . A small-scale randomized controlled trial of the revised new forest parenting programme for preschoolers with attention deficit hyperactivity disorder. Eur Child Adolesc Psychiatry. 2009;18(10):605–16. PMID: 19404717.19404717
Thurstone C, Riggs PD, Salomonsen-Sautel S, . Randomized, controlled trial of atomoxetine for attention-deficit/hyperactivity disorder in adolescents with substance use disorder. J Am Acad Child Adolesc Psychiatry. 2010;49(6):573–82. PMID: 20494267.20494267
Timler GR. Use of the Children’s Communication Checklist-2 for classification of language impairment risk in young school-age children with attention-deficit/hyperactivity disorder. Am J Speech Lang Pathol. 2014;23(1):73–83. PMID: 24018696.24018696
Toufic Seblany H, Ştefania Dinu I, Safer M, . Pharmacological treatment in stabilizing the symptoms in children with ADHD symptoms. Farmacia. 2013;61(5):1000–1008.
Tramontina S, Zeni CP, Ketzer CR, . Aripiprazole in children and adolescents with bipolar disorder comorbid with attention-deficit/hyperactivity disorder: a pilot randomized clinical trial. J Clin Psychiatry. 2009;70(5):756–64. PMID: 19389329.19389329
Tse YJ, McCarty CA, Stoep AV, . Teletherapy delivery of caregiver behavior training for children with attention-deficit hyperactivity disorder. Telemed J E Health. 2015;21(6):451–8. PMID: 25719609.25719609
Tsheringla S, Simon A, Russell PS, . ADD-H-Comprehensive Teacher’s Rating Scale (ACTeRS): a measure for attention deficit hyperactivity disorder among children with intellectual disability in India. Indian J Pediatr. 2014;81(Suppl 2):S161–4. PMID: 25265891.25265891
Tucha O, Tucha L, Kaumann G, . Training of attention functions in children with attention deficit hyperactivity disorder. Atten Defic Hyperact Disord. 2011;3(3):271–83. PMID: 21597880.21597880
Umar MU, Obindo JT and Omigbodun OO. Prevalence and Correlates of ADHD Among Adolescent Students in Nigeria. J Atten Disord. 2015. PMID: 26220786.26220786
Upadhyaya H, Kratochvil C, Ghuman J, . Efficacy and Safety Extrapolation Analyses for Atomoxetine in Young Children with Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2014. PMID: 25265343.25265343
van de Weijer-Bergsma E, Formsma AR, Bruin EI, . The effectiveness of mindfulness training on behavioral problems and attentional functioning in adolescents with ADHD. Journal of Child and Family Studies. 2012;21(5):775–787.22993482
van den Ban EF, Souverein PC, van Engeland H, . Differences in ADHD medication usage patterns in children and adolescents from different cultural backgrounds in the Netherlands. Soc Psychiatry Psychiatr Epidemiol. 2015;50(7):1153–62. PMID: 26017546.26017546
van den Hoofdakker BJ, Hoekstra PJ, van der Veen-Mulders L, . Paternal influences on treatment outcome of behavioral parent training in children with attention-deficit/hyperactivity disorder. Eur Child Adolesc Psychiatry. 2014;23(11):1071–9. PMID: 24878676.24878676
van der Donk ML, Hiemstra-Beernink AC, Tjeenk-Kalff AC, . Interventions to improve executive functioning and working memory in school-aged children with AD(H)D: a randomised controlled trial and stepped-care approach. BMC Psychiatry. 2013;13:23. PMID: 23311304.23311304
van der Kolk A, Bouwmans CA, Schawo SJ, . Association between quality of life and treatment response in children with attention Deficit Hyperactivity Disorder and their parents. J Ment Health Policy Econ. 2014;17(3):119–29. PMID: 25543115.25543115
van der Oord S, Ponsioen AJ, Geurts HM, . A pilot study of the efficacy of a computerized executive functioning remediation training with game elements for children with ADHD in an outpatient setting: outcome on parent- and teacher-rated executive functioning and ADHD behavior. J Atten Disord. 2014;18(8):699–712. PMID: 22879577.22879577
van der Oord S, Prins PJ, Oosterlaan J, . The adolescent outcome of children with attention deficit hyperactivity disorder treated with methylphenidate or methylphenidate combined with multimodal behaviour therapy: results of a naturalistic follow-up study. Clin Psychol Psychother. 2012;19(3):270–8. PMID: 21404369.21404369
Van Der Schans J, Kotsopoulos N, Hoekstra PJ, . Cost-effectiveness of extended-release methylphenidate in children and adolescents with attention-deficit/hyperactivity disorder sub-optimally treated with immediate release methylphenidate. PLoS ONE. 2015;10(5).
van Dongen-Boomsma M, Vollebregt MA, Slaats-Willemse D, . A randomized placebo-controlled trial of electroencephalographic (EEG) neurofeedback in children with attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2013;74(8):821–7. PMID: 24021501.24021501
van Rooij D, Hoekstra PJ, Mennes M, . Distinguishing Adolescents With ADHD From Their Unaffected Siblings and Healthy Comparison Subjects by Neural Activation Patterns During Response Inhibition. Am J Psychiatry. 2015;172(7):674–83. PMID: 25615565.25615565
Vander Stoep A and Myers K. Methodology for conducting the children’s attention-deficit hyperactivity disorder telemental health treatment study in multiple underserved communities. Clin Trials. 2013;10(6):949–58. PMID: 23897950.23897950
Vaughn AJ and Hoza B. The incremental utility of behavioral rating scales and a structured diagnostic interview in the assessment of attention-deficit/hyperactivity disorder. Journal of Emotional and Behavioral Disorders. 2013;21(4):227–239. PMID: 2013-38804-001.
Verkuijl N, Perkins M and Fazel M. Childhood attention-deficit/hyperactivity disorder. Bmj. 2015;350:h2168. PMID: 25994532.25994532
Vigliano P, Galloni GB, Bagnasco I, . Sleep in children with attention-deficit/hyperactivity disorder (ADHD) before and after 6-month treatment with methylphenidate: a pilot study. European Journal of Pediatrics. 2016;175(5):695–704.26833051
Villemonteix T, De Brito SA, Kavec M, . Grey matter volumes in treatment naive vs. chronically treated children with attention deficit/hyperactivity disorder: a combined approach. Eur Neuropsychopharmacol. 2015;25(8):1118–27. PMID: 25934396.25934396
Vogt C and Shameli A. Assessments for attention-deficit hyperactivity disorder: Use of objective measurements. Psychiatrist. 2011;35(10):380–383.
Vollebregt MA, van Dongen-Boomsma M, Buitelaar JK, . Does EEG-neurofeedback improve neurocognitive functioning in children with attention-deficit/hyperactivity disorder? A systematic review and a double-blind placebo-controlled study. J Child Psychol Psychiatry. 2014;55(5):460–72. PMID: 24168522.24168522
Wagner DJ, Vallerand IA and McLennan JD. Treatment receipt and outcomes from a clinic employing the attention-deficit/hyperactivity disorder treatment guideline of the children’s medication algorithm project. J Child Adolesc Psychopharmacol. 2014;24(9):472–80. PMID: 25329880.25329880
Wang LJ, Hsiao CC, Huang YS, . Association of salivary dehydroepiandrosterone levels and symptoms in patients with attention deficit hyperactivity disorder during six months of treatment with methylphenidate. Psychoneuroendocrinology. 2011;36(8):1209–16. PMID: 21411231.21411231
Waxmonsky JG, Waschbusch DA, Akinnusi O, . A comparison of atomoxetine administered as once versus twice daily dosing on the school and home functioning of children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2011;21(1):21–32. PMID: 21288121.21288121
Waxmonsky JG, Waschbusch DA, Pelham WE, . Effects of atomoxetine with and without behavior therapy on the school and home functioning of children with attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2010;71(11):1535–51. PMID: 20673557.20673557
Waxmonsky JG, Wymbs FA, Pariseau ME, . A novel group therapy for children with ADHD and severe mood dysregulation. J Atten Disord. 2013;17(6):527–41. PMID: 22373865.22373865
Weaver L, Rostain AL, Mace W, . Transcranial magnetic stimulation (TMS) in the treatment of attention-deficit/hyperactivity disorder in adolescents and young adults: a pilot study. J ect. 2012;28(2):98–103. PMID: 22551775.22551775
Wehmeier PM, Dittmann RW, Banaschewski T, . Does stimulant pretreatment modify atomoxetine effects on core symptoms of ADHD in children assessed by quantitative measurement technology?. J Atten Disord. 2014;18(2):105–16. PMID: 22617861.22617861
Wehmeier PM, Kipp L, Banaschewski T, . Does comorbid disruptive behavior modify the effects of atomoxetine on ADHD symptoms as measured by a continuous performance test and a motion tracking device?. Journal of Attention Disorders. 2015;19(7):591–602. PMID: 2015-29687-004.22930789
Wehmeier PM, Schacht A, Dittmann RW, . Effect of atomoxetine on quality of life and family burden: results from a randomized, placebo-controlled, double-blind study in children and adolescents with ADHD and comorbid oppositional defiant or conduct disorder. Qual Life Res. 2011;20(5):691–702. PMID: 21136299.21136299
Wehmeier PM, Schacht A, Escobar R, . Health-related quality of life in ADHD: a pooled analysis of gender differences in five atomoxetine trials. Atten Defic Hyperact Disord. 2012;4(1):25–35. PMID: 22271466.22271466
Wehmeier PM, Schacht A, Ulberstad F, . Does atomoxetine improve executive function, inhibitory control, and hyperactivity? Results from a placebo-controlled trial using quantitative measurement technology. J Clin Psychopharmacol. 2012;32(5):653–60. PMID: 22926599.22926599
Wehmeier PM, Schacht A, Wolff C, . Neuropsychological outcomes across the day in children with attention-deficit/hyperactivity disorder treated with atomoxetine: results from a placebo-controlled study using a computer-based continuous performance test combined with an infra-red motion-tracking device. J Child Adolesc Psychopharmacol. 2011;21(5):433–44. PMID: 22040189.22040189
Weisler RH, Adler LA, Kollins SH, . Analysis of individual items on the attention-deficit/hyperactivity disorder symptom rating scale in children and adults: the effects of age and sex in pivotal trials of lisdexamfetamine dimesylate. Neuropsychiatr Dis Treat. 2014;10:1–12. PMID: 24363557.24363557
Weiss M, Panagiotopoulos C, Giles L, . A naturalistic study of predictors and risks of atypical antipsychotic use in an attention-deficit/hyperactivity disorder clinic. J Child Adolesc Psychopharmacol. 2009;19(5):575–82. PMID: 19877982.19877982
Wentz E, Nyden A and Krevers B. Development of an internet-based support and coaching model for adolescents and young adults with ADHD and autism spectrum disorders: a pilot study. Eur Child Adolesc Psychiatry. 2012;21(11):611–22. PMID: 22736195.22736195
Whalen CK, Henker B, Ishikawa SS, . Atomoxetine versus stimulants in the community treatment of children with ADHD: an electronic diary study. J Atten Disord. 2010;13(4):391–400. PMID: 19474461.19474461
Wiesner M, Windle M, Kanouse DE, . DISC Predictive Scales (DPS): Factor Structure and Uniform Differential Item Functioning Across Gender and Three Racial/Ethnic Groups for ADHD, Conduct Disorder, and Oppositional Defiant Disorder Symptoms. Psychol Assess. 2015. PMID: 25774639.25774639
Wietecha L, Williams D, Shaywitz S, . Atomoxetine improved attention in children and adolescents with attention-deficit/hyperactivity disorder and dyslexia in a 16 week, acute, randomized, double-blind trial. J Child Adolesc Psychopharmacol. 2013;23(9):605–13. PMID: 24206099.24206099
Wietecha LA, Ruff DD, Allen AJ, . Atomoxetine tolerability in pediatric and adult patients receiving different dosing strategies. J Clin Psychiatry. 2013;74(12):1217–23. PMID: 24434090.24434090
Wigal SB, Childress AC, Belden HW, . NWP06, an extended-release oral suspension of methylphenidate, improved attention-deficit/hyperactivity disorder symptoms compared with placebo in a laboratory classroom study. J Child Adolesc Psychopharmacol. 2013;23(1):3–10. PMID: 23289899.23289899
Wigal SB, Greenhill LL, Nordbrock E, . A randomized placebo-controlled double-blind study evaluating the time course of response to methylphenidate hydrochloride extended-release capsules in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2014;24(10):562–9. PMID: 25470572.25470572
Wigal SB, Jun A, Wong AA, . Does prior exposure to stimulants in children with ADHD impact cardiovascular parameters from lisdexamfetamine dimesylate?. Postgrad Med. 2010;122(5):27–34. PMID: 20861585.20861585
Wigal SB, Kollins SH, Childress AC, . A 13-hour laboratory school study of lisdexamfetamine dimesylate in school-aged children with attention-deficit/hyperactivity disorder. Child Adolesc Psychiatry Ment Health. 2009;3(1):17. PMID: 19508731.19508731
Wigal SB, Kollins SH, Childress AC, . Efficacy and tolerability of lisdexamfetamine dimesylate in children with attention-deficit/hyperactivity disorder: sex and age effects and effect size across the day. Child Adolesc Psychiatry Ment Health. 2010;4:32. PMID: 21156071.21156071
Wigal SB, Nordbrock E, Adjei AL, . Efficacy of Methylphenidate Hydrochloride Extended-Release Capsules (Aptensio XR) in Children and Adolescents with Attention-Deficit/Hyperactivity Disorder: A Phase III, Randomized, Double-Blind Study. CNS Drugs. 2015;29(4):331–40. PMID: 25877989.25877989
Wigal SB, Wigal T, Schuck S, . Academic, behavioral, and cognitive effects of OROS(R) methylphenidate on older children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2011;21(2):121–31. PMID: 21488750.21488750
Wigal SB, Wong AA, Jun A, . Adverse events in medication treatment-naive children with attention-deficit/hyperactivity disorder: results from a small, controlled trial of lisdexamfetamine dimesylate. J Child Adolesc Psychopharmacol. 2012;22(2):149–56. PMID: 22372513.22372513
Wilens TE, Bukstein O, Brams M, . A controlled trial of extended-release guanfacine and psychostimulants for attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2012;51(1):74–85.e2. PMID: 22176941.22176941
Wilens TE, Gault LM, Childress A, . Safety and efficacy of ABT-089 in pediatric attention-deficit/hyperactivity disorder: results from two randomized placebo-controlled clinical trials. J Am Acad Child Adolesc Psychiatry. 2011;50(1):73–84.e1. PMID: 21156272.21156272
Wilens TE, Hammerness P, Martelon M, . A controlled trial of the methylphenidate transdermal system on before-school functioning in children with attention-deficit/hyperactivity disorder. J Clin Psychiatry. 2010;71(5):548–56. PMID: 20492851.20492851
Wilens TE, Hammerness P, Utzinger L, . An open study of adjunct OROS-methylphenidate in children and adolescents who are atomoxetine partial responders: I. Effectiveness. J Child Adolesc Psychopharmacol. 2009;19(5):485–92. PMID: 19877972.19877972
Wilens TE, McBurnett K, Turnbow J, . Morning and Evening Effects of Guanfacine Extended Release Adjunctive to Psychostimulants in Pediatric ADHD: Results From a Phase III Multicenter Trial. J Atten Disord. 2013. PMID: 24071772.24071772
Wilens TE, Robertson B, Sikirica V, . A Randomized, Placebo-Controlled Trial of Guanfacine Extended Release in Adolescents With Attention-Deficit/Hyperactivity Disorder. J Am Acad Child Adolesc Psychiatry. 2015;54(11):916–925.e2. PMID: 26506582.26506582
Wilkes S, Cordier R, Bundy A, . A play-based intervention for children with ADHD: a pilot study. Aust Occup Ther J. 2011;58(4):231–40. PMID: 21770958.21770958
Wilkes-Gillan S, Bundy A, Cordier R, . Eighteen-month follow-up of a play-based intervention to improve the social play skills of children with attention deficit hyperactivity disorder. Aust Occup Ther J. 2014;61(5):299–307. PMID: 24762264.24762264
Williamson D, Murray DW, Damaraju CV, . Methylphenidate in children with ADHD with or without learning disability. J Atten Disord. 2014;18(2):95–104. PMID: 22628142.22628142
Wills HP and Mason BA. Implementation of a self-monitoring application to improve on-task behavior: A high-school pilot study. Journal of Behavioral Education. 2014;23(4):421–434.26617453
Winter W and Sheridan M. Previous reward decreases errors of commission on later ‘No-Go’ trials in children 4 to 12 years of age: Evidence for a context monitoring account. Developmental Science. 2014;17(5):797–807.24636228
Winterstein AG, Gerhard T, Kubilis P, . Cardiovascular safety of central nervous system stimulants in children and adolescents: population based cohort study. Bmj. 2012;345:e4627. PMID: 22809800.22809800
Wolraich ML, Bard DE, Neas B, . The psychometric properties of the Vanderbilt attention-deficit hyperactivity disorder diagnostic teacher rating scale in a community population. J Dev Behav Pediatr. 2013;34(2):83–93. PMID: 23363973.23363973
Wong CG and Stevens MC. The effects of stimulant medication on working memory functional connectivity in attention-deficit/hyperactivity disorder. Biol Psychiatry. 2012;71(5):458–66. PMID: 22209640.22209640
Woodruff DB, El-Mallakh RS and Thiruvengadam AP. A potential diagnostic blood test for attention deficit hyperactivity disorder. Atten Defic Hyperact Disord. 2011;3(3):265–9. PMID: 21523444.21523444
Wrońska N, Garcia-Zapirain B and Mendez-Zorrilla A. An iPad-based tool for improving the skills of children with attention deficit disorder. International Journal of Environmental Research and Public Health. 2015;12(6):6261–6280.26042366
Xiaoli Y, Chao J, Wen P, . Prevalence of psychiatric disorders among children and adolescents in northeast China. PLoS One. 2014;9(10):e111223. PMID: 25360718.25360718
Xie Y, Dixon JF, Yee OM, . A study on the effectiveness of videoconferencing on teaching parent training skills to parents of children with ADHD. Telemed J E Health. 2013;19(3):192–9. PMID: 23405952.23405952
Yang L, Cao Q, Shuai L, . Comparative study of OROS-MPH and atomoxetine on executive function improvement in ADHD: a randomized controlled trial. Int J Neuropsychopharmacol. 2012;15(1):15–26. PMID: 22017969.22017969
Yang R, Gao W, Li R, . Effect of Atomoxetine on the Cognitive Functions in Treatment of Attention Deficit Hyperactivity Disorder in Children with Congenital Hypothyroidism: A Pilot Study. Int J Neuropsychopharmacol. 2015;18(8). PMID: 25896257.25896257
Yazd SN, Ayatizadeh F, Dehghan F, . Comparing the effects of drug therapy, perceptual motor training, and both combined on the motor skills of school-aged attention deficit hyperactivity disorder children. CNS Neurol Disord Drug Targets. 2015. PMID: 26556079.26556079
Yildiz O, Sismanlar SG, Memik NC, . Atomoxetine and methylphenidate treatment in children with ADHD: the efficacy, tolerability and effects on executive functions. Child Psychiatry Hum Dev. 2011;42(3):257–69. PMID: 21165694.21165694
Young J, Rugino T, Dammerman R, . Efficacy of guanfacine extended release assessed during the morning, afternoon, and evening using a modified Conners’ Parent Rating Scale-revised: Short Form. J Child Adolesc Psychopharmacol. 2014;24(8):435–41. PMID: 25286026.25286026
Yousefi Chaijan P, Sharafkhah M, Salehi B, . Attention deficit hyperactivity disorder in children with early stages of chronic kidney disease. Med J Islam Repub Iran. 2015;29:181. PMID: 26034734.26034734
Zarinara AR, Mohammadi MR, Hazrati N, . Venlafaxine versus methylphenidate in pediatric outpatients with attention deficit hyperactivity disorder: a randomized, double-blind comparison trial. Hum Psychopharmacol. 2010;25(7–8):530–5. PMID: 20860068.20860068
Zeni CP, Tramontina S, Ketzer CR, . Methylphenidate combined with aripiprazole in children and adolescents with bipolar disorder and attention-deficit/hyperactivity disorder: a randomized crossover trial. J Child Adolesc Psychopharmacol. 2009;19(5):553–61. PMID: 19877980.19877980
Zheng Y, Wang YF, Qin J, . Prospective, naturalistic study of open-label OROS methylphenidate treatment in Chinese school-aged children with attention-deficit/hyperactivity disorder. Chin Med J (Engl). 2011;124(20):3269–74. PMID: 22088519.22088519
Ziereis S and Jansen P. Effects of physical activity on executive function and motor performance in children with ADHD. Res Dev Disabil. 2015;38:181–91. PMID: 25561359.25561359

### Does Not Report Data for a Study Population of Interest

Adler LA, Shaw DM, Spencer TJ, . Preliminary reliability and validity of a new time-sensitive ADHD symptom scale in adolescents with ADHD. Postgrad Med. 2011;123(5):7–13. PMID: 21904082.21904082
Aghebati A, Gharraee B, Hakim Shoshtari M, . Triple p-positive parenting program for mothers of ADHD children. Iran J Psychiatry Behav Sci. 2014;8(1):59–65. PMID: 24995031.24995031
Algorta GP, Dodd AL, Stringaris A, . Diagnostic efficiency of the SDQ for parents to identify ADHD in the UK: a ROC analysis. Eur Child Adolesc Psychiatry. 2016. PMID: 26762184.26762184
Alqaryouti IA, Abu Hilar MM and Ibrahim MM. Validity and reliability of an attention deficit and hyperactivity disorder measure among a sample of Omani children. Electronic Journal of Research in Educational Psychology. 2011;9(2):911–930.
Aman MG, Bukstein OG, Gadow KD, . What does risperidone add to parent training and stimulant for severe aggression in child attention-deficit/hyperactivity disorder?. J Am Acad Child Adolesc Psychiatry. 2014;53(1):47–60.e1. PMID: 24342385.24342385
Anastopoulos AD and King KA. A Cognitive-Behavior Therapy and Mentoring Program for College Students With ADHD. Cognitive and Behavioral Practice. 2015;22(2):141–151.
Arnold LE, Gadow KD, Farmer CA, . Comorbid anxiety and social avoidance in treatment of severe childhood aggression: response to adding risperidone to stimulant and parent training; mediation of disruptive symptom response. J Child Adolesc Psychopharmacol. 2015;25(3):203–12. PMID: 25885010.25885010
Azevedo AF, Seabra-Santos MJ, Gaspar MF, . The Incredible Years Basic Parent Training for Portuguese preschoolers with AD/HD behaviors: Does it make a difference?. Child & Youth Care Forum. 2013;42(5):403–424..
Barnard-Brak L, To YM and Fearon DD. Protopathic stimulant use among children with symptoms of ADHD. Atten Defic Hyperact Disord. 2011;3(3):245–51. PMID: 21452045.21452045
Baskin BM, Dwoskin LP and Kantak KM. Methylphenidate treatment beyond adolescence maintains increased cocaine self-administration in the spontaneously hypertensive rat model of attention deficit/hyperactivity disorder. Pharmacol Biochem Behav. 2015;131:51–6. PMID: 25643872.25643872
Batzle CS, Weyandt LL, Janusis GM, . Potential impact of ADHD with stimulant medication label on teacher expectations. Journal of Attention Disorders. 2010;14(2):157–166.19773600
Bledsoe JC, Xiao D, Chaovalitwongse A, . Diagnostic Classification of ADHD Versus Control: Support Vector Machine Classification Using Brief Neuropsychological Assessment. J Atten Disord. 2016. PMID: 27231214.27231214
Breda V, Rovaris DL, Vitola ES, . Does collateral retrospective information about childhood attention-deficit/hyperactivity disorder symptoms assist in the diagnosis of attention-deficit/hyperactivity disorder in adults? Findings from a large clinical sample. Aust N Z J Psychiatry. 2015. PMID: 26460329.26460329
Brown TE, Brams M, Gasior M, . Clinical utility of ADHD symptom thresholds to assess normalization of executive function with lisdexamfetamine dimesylate treatment in adults. Curr Med Res Opin. 2011;27(Suppl 2):23–33. PMID: 21973229.21973229
Burns GL, Walsh JA, Servera M, . Construct validity of ADHD/ODD rating scales: recommendations for the evaluation of forthcoming DSM-V ADHD/ODD scales. J Abnorm Child Psychol. 2013;41(1):15–26. PMID: 22773361.22773361
Burton B, Grant M, Feigenbaum A, . A randomized, placebo-controlled, double-blind study of sapropterin to treat ADHD symptoms and executive function impairment in children and adults with sapropterin-responsive phenylketonuria. Molecular Genetics and Metabolism. 2015;114(3):415–424.25533024
Calarge CA, Schlechte JA, Burns TL, . The effect of psychostimulants on skeletal health in boys co-treated with risperidone. Journal of Pediatrics. 2015;166(6):1449–1454.e1.25863660
Camporeale A, Day KA, Ruff D, . Profile of sexual and genitourinary treatment-emergent adverse events associated with atomoxetine treatment: a pooled analysis. Drug Saf. 2013;36(8):663–71. PMID: 23775507.23775507
Canivez GL and Gaboury AR. Construct Validity and Diagnostic Utility of the Cognitive Assessment System for ADHD. J Atten Disord. 2013. PMID: 23757332.23757332
Canu WH and Bearman SK. Community-clinic-based parent intervention addressing noncompliance in children with attention-deficit/hyperactivity disorder. Cognitive and Behavioral Practice. 2011;18(4):491–501.
Chang Z, Lichtenstein P, Halldner L, . Stimulant ADHD medication and risk for substance abuse. Journal of Child Psychology and Psychiatry. 2014;55(8):878–885.25158998
Charach A, Lin E and To T. Evaluating the Hyperactivity/Inattention Subscale of the National Longitudinal Survey of Children and Youth. Health Rep. 2010;21(2):43–50. PMID: 20632524.20632524
Chen CY, Yeh HH, Chen KH, . Differential effects of predictors on methylphenidate initiation and discontinuation among young people with newly diagnosed attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2011;21(3):265–73. PMID: 21663429.21663429
Chen Q, Sjolander A, Runeson B, . Drug treatment for attention-deficit/hyperactivity disorder and suicidal behaviour: register based study. Bmj. 2014;348:g3769. PMID: 24942388.24942388
Coben R and Myers TE. Sensitivity and specificity of long wave infrared imaging for attention-deficit/hyperactivity disorder. J Atten Disord. 2009;13(1):56–65. PMID: 19429882.19429882
Cooper WO, Habel LA, Sox CM, . ADHD drugs and serious cardiovascular events in children and young adults. N Engl J Med. 2011;365(20):1896–904. PMID: 22043968.22043968
Cordeiro ML, Farias AC, Whybrow PC, . Receiver Operating Characteristic Curve Analysis of Screening Tools for Bipolar Disorder Comorbid With ADHD in Schoolchildren. J Atten Disord. 2015. PMID: 26721636.26721636
Corkum P, Elik N, Blotnicky-Gallant PA, . Web-Based Intervention for Teachers of Elementary Students With ADHD: Randomized Controlled Trial. J Atten Disord. 2015. PMID: 26362259.26362259
Croft S, Stride C, Maughan B, . Validity of the strengths and difficulties questionnaire in preschool-aged children. Pediatrics. 2015;135(5):e1210–9. PMID: 25847804.25847804
Dalsgaard S, Leckman JF, Mortensen PB, . Effect of drugs on the risk of injuries in children with attention deficit hyperactivity disorder: a prospective cohort study. Lancet Psychiatry. 2015;2(8):702–9. PMID: 26249301.26249301
Dalsgaard S, Nielsen HS and Simonsen M. Consequences of ADHD medication use for children’s outcomes. Journal of Health Economics. 2014;37(1):137–151.24997381
de la Osa N, Granero R, Penelo E, . The short and very short forms of the Children’s Behavior Questionnaire in a community sample of preschoolers. Assessment. 2014;21(4):463–76. PMID: 24235176.24235176
Delavarian M, Towhidkhah F, Dibajnia P, . Designing a decision support system for distinguishing ADHD from similar children behavioral disorders. J Med Syst. 2012;36(3):1335–43. PMID: 20878211.20878211
Delavarian M, Towhidkhah F, Gharibzadeh S, . Automatic classification of hyperactive children: comparing multiple artificial intelligence approaches. Neurosci Lett. 2011;498(3):190–3. PMID: 21396979.21396979
Doerfler LA, Connor DF and Toscano PF, Jr.. Aggression, ADHD symptoms, and dysphoria in children and adolescents diagnosed with bipolar disorder and ADHD. J Affect Disord. 2011;131(1–3):312–9. PMID: 21168917.21168917
Durell TM, Adler LA, Williams DW, . Atomoxetine treatment of attention-deficit/hyperactivity disorder in young adults with assessment of functional outcomes: a randomized, double-blind, placebo-controlled clinical trial. J Clin Psychopharmacol. 2013;33(1):45–54. PMID: 23277268.23277268
Efstratopoulou M, Simons J and Janssen R. Concordance among physical educators’, teachers’, and parents’ perceptions of attention problems in children. J Atten Disord. 2013;17(5):437–43. PMID: 22323118.22323118
Eichelberger I, Plück J, Hautmann C, . Eff ectiveness of the Prevention Program for Externalizing Problem Behavior (PEP) in Preschoolers with Severe and No or Mild ADHD Symptoms. Zeitschrift fur Kinder- und Jugendpsychiatrie und Psychotherapie. 2016;44(3):231–239.27216329
Elkins RM, Carpenter AL, Pincus DB, . Inattention symptoms and the diagnosis of comorbid attention-deficit/hyperactivity disorder among youth with generalized anxiety disorder. J Anxiety Disord. 2014;28(8):754–60. PMID: 25260213.25260213
Epstein JN, Langberg JM, Lichtenstein PK, . Use of an Internet portal to improve community-based pediatric ADHD care: a cluster randomized trial. Pediatrics. 2011;128(5):e1201–8. PMID: 22007005.22007005
Evans WN, Morrill MS and Parente ST. Measuring inappropriate medical diagnosis and treatment in survey data: The case of ADHD among school-age children. J Health Econ. 2010;29(5):657–73. PMID: 20739076.20739076
Follan M, Anderson S, Huline-Dickens S, . Discrimination between attention deficit hyperactivity disorder and reactive attachment disorder in school aged children. Res Dev Disabil. 2011;32(2):520–6. PMID: 21257287.21257287
Fowler PJ, Henry DB, Schoeny M, . Effects of the SAFE Children preventive intervention on developmental trajectories of attention-deficit/hyperactivity disorder symptoms. Dev Psychopathol. 2014;26(4 Pt 1):1161–79. PMID: 24713426.24713426
Franke N, Keown LJ and Sanders MR. An RCT of an Online Parenting Program for Parents of Preschool-Aged Children With ADHD Symptoms. J Atten Disord. 2016. PMID: 27609783.27609783
Freeman NC, Gray KM, Taffe JR, . Development of a new attention rating scale for children with intellectual disability: The Scale of Attention in Intellectual Disability (SAID). American Journal on Intellectual and Developmental Disabilities. 2015;120(2):91–109.25715180
Frindik JP, Morales A, Fowlkes J, . Stimulant medication use and response to growth hormone therapy: an NCGS database analysis. Horm Res. 2009;72(3):160–6. PMID: 19729947.19729947
Fujibayashi H, Kitayama S and Matsuo M. Score of inattention subscale of ADHD rating scale-IV is significantly higher for AD/HD than PDD. Kobe J Med Sci. 2010;56(1):E12–7. PMID: 21063141.21063141
Gadow KD, Arnold LE, Molina BS, . Risperidone added to parent training and stimulant medication: effects on attention-deficit/hyperactivity disorder, oppositional defiant disorder, conduct disorder, and peer aggression. J Am Acad Child Adolesc Psychiatry. 2014;53(9):948–959.e1. PMID: 25151418.25151418
Garcia Fernandez T, Gonzalez-Pienda JA, Rodriguez Perez C, . Psychometric characteristics of the BRIEF scale for the assessment of executive functions in Spanish clinical population. Psicothema. 2014;26(1):47–52. PMID: 24444729.24444729
Ghanizadeh A. Psychometric analysis of the new ADHD DSM-V derived symptoms. BMC Psychiatry. 2012;12:21. PMID: 22433111.22433111
Gjevik E, Sandstad B, Andreassen OA, . Exploring the agreement between questionnaire information and DSM-IV diagnoses of comorbid psychopathology in children with autism spectrum disorders. Autism. 2015;19(4):433–42. PMID: 24637430.24637430
Gonzalez-Heydrich J, Hsin O, Gumlak S, . Comparing stimulant effects in youth with ADHD symptoms and epilepsy. Epilepsy Behav. 2014;36:102–7. PMID: 24907495.24907495
Goodman D, Faraone SV, Adler LA, . Interpreting ADHD rating scale scores: Linking ADHD rating scale scores and CGI levels in two randomized controlled trials of lisdexamfetamine dimesylate in ADHD. Primary Psychiatry. 2010;17(3):44–52.
Gordon HA, Rucklidge JJ, Blampied NM, . Clinically Significant Symptom Reduction in Children with Attention-Deficit/Hyperactivity Disorder Treated with Micronutrients: An Open-Label Reversal Design Study. J Child Adolesc Psychopharmacol. 2015;25(10):783–98. PMID: 26682999.26682999
Hagen KA and Ogden T. Predictors of changes in child behaviour following parent management training: Child, context, and therapy factors. Int J Psychol. 2016. PMID: 27425781.27425781
Handen BL, Aman MG, Arnold LE, . Atomoxetine, Parent Training, and Their Combination in Children With Autism Spectrum Disorder and Attention-Deficit/Hyperactivity Disorder. J Am Acad Child Adolesc Psychiatry. 2015;54(11):905–15. PMID: 26506581.26506581
Harfterkamp M, van der Meer D, van der Loo-Neus G, . No evidence for predictors of response to atomoxetine treatment of attention-deficit/hyperactivity disorder symptoms in children and adolescents with autism spectrum disorder. Journal of Child and Adolescent Psychopharmacology. 2015;25(4):372–375.25919900
Hatakenaka Y, Kotani H, Yasumitsu-Lovell K, . Infant Motor Delay and Early Symptomatic Syndromes Eliciting Neurodevelopmental Clinical Examinations in Japan. Pediatr Neurol. 2016;54:55–63. PMID: 26706480.26706480
Herbert SD, Harvey EA, Roberts JL, . A randomized controlled trial of a parent training and emotion socialization program for families of hyperactive preschool-aged children. Behav Ther. 2013;44(2):302–16. PMID: 23611079.23611079
Heubeck BG, Otte TA and Lauth GW. Consumer evaluation and satisfaction with individual versus group parent training for children with hyperkinetic disorder (HKD). Br J Clin Psychol. 2016;55(3):305–19. PMID: 26660709.26660709
Hodgkins P, Sasane R, Christensen L, . Treatment outcomes with methylphenidate formulations among patients with ADHD: retrospective claims analysis of a managed care population. Curr Med Res Opin. 2011;27(Suppl 2):53–62. PMID: 21973231.21973231
Holmberg K, Sundelin C and Hjern A. Screening for attention-deficit/hyperactivity disorder (ADHD): can high-risk children be identified in first grade?. Child Care Health Dev. 2013;39(2):268–76. PMID: 22515618.22515618
Hondebrink L, Rietjens SJ, Hunault CC, . Methylphenidate intoxications in children and adults: exposure circumstances and evidence-based dose threshold for pre-hospital triage. Clin Toxicol (Phila). 2015;53(3):168–77. PMID: 25650984.25650984
Hoza B, Smith AL, Shoulberg EK, . A randomized trial examining the effects of aerobic physical activity on attention-deficit/hyperactivity disorder symptoms in young children. J Abnorm Child Psychol. 2015;43(4):655–67. PMID: 25201345.25201345
Hult N, Kadesjo J, Kadesjo B, . ADHD and the QbTest: Diagnostic Validity of QbTest. J Atten Disord. 2015. PMID: 26224575.26224575
Huss M, Ginsberg Y, Arngrim T, . Open-label dose optimization of methylphenidate modified release long acting (MPH-LA): a post hoc analysis of real-life titration from a 40-week randomized trial. Clin Drug Investig. 2014;34(9):639–49. PMID: 25015027.25015027
Hwang JW, Kim B, Kim Y, . Methylphenidate-osmotic-controlled release oral delivery system treatment reduces parenting stress in parents of children and adolescents with attention-deficit/hyperactivity disorder. Hum Psychopharmacol. 2013;28(6):600–7. PMID: 24519694.24519694
Ise E, Kierfeld F and Dopfner M. One-year follow-up of guided self-help for parents of preschool children with externalizing behavior. J Prim Prev. 2015;36(1):33–40. PMID: 25331981.25331981
Johnson M, Fransson G, Ostlund S, . Omega 3/6 fatty acids for reading in children: a randomized, double-blind, placebo-controlled trial in 9-year-old mainstream schoolchildren in Sweden. J Child Psychol Psychiatry. 2016. PMID: 27545509.27545509
Johnson S, Hollis C, Marlow N, . Screening for childhood mental health disorders using the Strengths and Difficulties Questionnaire: the validity of multi-informant reports. Dev Med Child Neurol. 2014;56(5):453–9. PMID: 24410039.24410039
Kim J, Kim G and Seo S. Validation of the FSA as screening tool for children with ADHD. Arts in Psychotherapy. 2014;41(4):413–423.
Ko HJ, Kim I, Kim JB, . Effects of Korean red ginseng extract on behavior in children with symptoms of inattention and hyperactivity/impulsivity: a double-blind randomized placebo-controlled trial. J Child Adolesc Psychopharmacol. 2014;24(9):501–8. PMID: 25369174.25369174
Kolko DJ, Campo J, Kilbourne AM, . Collaborative care outcomes for pediatric behavioral health problems: a cluster randomized trial. Pediatrics. 2014;133(4):e981–92. PMID: 24664093.24664093
Korsch F and Petermann F. Agreement between parents and teachers on preschool children’s behavior in a clinical sample with externalizing behavioral problems. Child Psychiatry Hum Dev. 2014;45(5):617–27. PMID: 24363143.24363143
Kratochvil CJ, May DE, Silva SG, . Treatment response in depressed adolescents with and without co-morbid attention-deficit/hyperactivity disorder in the Treatment for Adolescents with Depression Study. J Child Adolesc Psychopharmacol. 2009;19(5):519–27. PMID: 19877976.19877976
Kraut AA, Langner I, Lindemann C, . Comorbidities in ADHD children treated with methylphenidate: a database study. BMC Psychiatry. 2013;13:11. PMID: 23294623.23294623
Kudo M, Altamirano W, Mearns J, . SWAN Preschool Rating Scale (SWAN-P): Validity evidence for English and Spanish versions. The International Journal of Educational and Psychological Assessment. 2012;10(1):139–157.
Laezer KL. Effectiveness of psychoanalytic psychotherapy and behavioral therapy treatment in children with attention deficit hyperactivity disorder and oppositional defiant disorder. Journal of Infant, Child & Adolescent Psychotherapy. 2015;14(2):111–128.
Landaas ET, Halmoy A, Oedegaard KJ, . The impact of cyclothymic temperament in adult ADHD. J Affect Disord. 2012;142(1–3):241–7. PMID: 22840630.22840630
Lange H, Buse J, Bender S, . Accident proneness in children and adolescents affected by ADHD and the impact of medication. Journal of Attention Disorders. 2016;20(6):501–509. PMID: 2016-22077-004.24470540
Larson T, Lundstrom S, Nilsson T, . Predictive properties of the A-TAC inventory when screening for childhood-onset neurodevelopmental problems in a population-based sample. BMC Psychiatry. 2013;13:233. PMID: 24066834.24066834
Lecavalier L, Gadow KD, Devincent CJ, . Validity of DSM-IV syndromes in preschoolers with autism spectrum disorders. Autism. 2011;15(5):527–43. PMID: 21454388.21454388
Leuchter AF, McGough JJ, Korb AS, . Neurophysiologic predictors of response to atomoxetine in young adults with attention deficit hyperactivity disorder: a pilot project. J Psychiatr Res. 2014;54:11–8. PMID: 24726639.24726639
Limbers CA, Ripperger-Suhler J, Heffer RW, . Patient-reported Pediatric Quality of Life Inventory 4.0 Generic Core Scales in pediatric patients with attention-deficit/hyperactivity disorder and comorbid psychiatric disorders: feasibility, reliability, and validity. Value Health. 2011;14(4):521–30. PMID: 21315637.21315637
Linden S, Bussing R, Kubilis P, . Risk of Suicidal Events With Atomoxetine Compared to Stimulant Treatment: A Cohort Study. Pediatrics. 2016;137(5). PMID: 27244795.27244795
Loutfi KS, Carvalho AM, Lamounier JA, . ADHD and epilepsy: contributions from the use of behavioral rating scales to investigate psychiatric comorbidities. Epilepsy Behav. 2011;20(3):484–9. PMID: 21300573.21300573
Lufi D and Fichman N. Development and use of a computerized test, MATH-CPT, to assess attention. Percept Mot Skills. 2012;114(1):59–74. PMID: 22582676.22582676
Makransky G and Bilenberg N. Psychometric properties of the parent and teacher ADHD Rating Scale (ADHD-RS): measurement invariance across gender, age, and informant. Assessment. 2014;21(6):694–705. PMID: 24852496.24852496
Man KKC, Chan EW, Coghill D, . Methylphenidate and the risk of trauma. Pediatrics. 2015;135(1):40–48.25511122
Manor I, Newcorn JH, Faraone SV, . Efficacy of metadoxine extended release in patients with predominantly inattentive subtype attention-deficit/hyperactivity disorder. Postgrad Med. 2013;125(4):181–90. PMID: 23933905.23933905
Marshall P, Schroeder R, O’Brien J, . Effectiveness of symptom validity measures in identifying cognitive and behavioral symptom exaggeration in adult attention deficit hyperactivity disorder. Clin Neuropsychol. 2010;24(7):1204–37. PMID: 20845231.20845231
Martel MM, Schimmack U, Nikolas M, . Integration of symptom ratings from multiple informants in ADHD diagnosis: A psychometric model with clinical utility. Psychological Assessment. 2015;27(3):1060–1071.25730162
Martin P, Satin L, Kahn RS, . A thorough QT study of guanfacine. Int J Clin Pharmacol Ther. 2015;53(4):301–16. PMID: 25109412.25109412
Masi G, Milone A, Manfredi A, . Combined pharmacotherapy-multimodal psychotherapy in children with Disruptive Behavior Disorders. Psychiatry Research. 2016;238:8–13.27086204
Masi G, Pisano S, Milone A, . Child behavior checklist dysregulation profile in children with disruptive behavior disorders: A longitudinal study. J Affect Disord. 2015;186:249–53. PMID: 26254616.26254616
McCarthy S, Wilton L, Murray ML, . Persistence of pharmacological treatment into adulthood, in UK primary care, for ADHD patients who started treatment in childhood or adolescence. BMC Psychiatry. 2012;12(1).
McConaughy SH, Harder VS, Antshel KM, . Incremental validity of test session and classroom observations in a multimethod assessment of attention deficit/hyperactivity disorder. J Clin Child Adolesc Psychol. 2010;39(5):650–66. PMID: 20706918.20706918
McConaughy SH, Ivanova MY, Antshel K, . Standardized Observational Assessment of Attention Deficit Hyperactivity Disorder Combined and Predominantly Inattentive Subtypes. II. Classroom Observations. School Psych Rev. 2009;38(3):362–381. PMID: 20802813.20802813
Melegari MG, Sacco R, Manzi B, . Deficient Emotional Self-Regulation in Preschoolers With ADHD: Identification, Comorbidity, and Interpersonal Functioning. J Atten Disord. 2016. PMID: 26744314.26744314
Miller BS, Aydin F, Lundgren F, . Stimulant use and its impact on growth in children receiving growth hormone therapy: an analysis of the KIGS International Growth Database. Horm Res Paediatr. 2014;82(1):31–7. PMID: 24924157.24924157
Miranda A, Colomer C, Mercader J, . Performance-based tests versus behavioral ratings in the assessment of executive functioning in preschoolers: associations with ADHD symptoms and reading achievement. Front Psychol. 2015;6:545. PMID: 25972833.25972833
Miranda MC, Barbosa T, Muszkat M, . Performance patterns in Conners’ CPT among children with attention deficit hyperactivity disorder and dyslexia. Arq Neuropsiquiatr. 2012;70(2):91–6. PMID: 22311211.22311211
Missiuna C, Cairney J, Pollock N, . A staged approach for identifying children with developmental coordination disorder from the population. Res Dev Disabil. 2011;32(2):549–59. PMID: 21216564.21216564
Molife C, Bernauer MJ, Farr AM, . Combination therapy patterns and predictors of ADHD in commercially insured and Medicaid populations. Postgrad Med. 2012;124(5):7–22. PMID: 23095422.23095422
Moore RM. Reliable ratings or reading tea leaves: Can parent, teacher, and clinician behavioral ratings of preschoolers predict ADHD at age six?. Journal of Developmental and Behavioral Pediatrics. 2014;35(7):471–471.
Munkvold LH, Manger T and Lundervold AJ. Conners’ continuous performance test (CCPT-II) in children with ADHD/ODD, or a combined ADHD/ODD diagnosis. Child Neuropsychology. 2014;20(1):106–126.23244393
Nazhvani AD, Boostani R, Afrasiabi S, . Classification of ADHD and BMD patients using visual evoked potential. Clin Neurol Neurosurg. 2013;115(11):2329–35. PMID: 24050849.24050849
Newman E and Reddy LA. Diagnostic Utility of the Pediatric Attention Disorders Diagnostic Screener. J Atten Disord. 2014. PMID: 24639402.24639402
Nielsen NP and Wiig EH. Validation of the AQT color-form additive model for screening and monitoring pharmacological treatment of ADHD. J Atten Disord. 2013;17(3):187–93. PMID: 22210798.22210798
Olfson M, Huang C, Gerhard T, . Stimulants and cardiovascular events in youth with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 2012;51(2):147–56. PMID: 22265361.22265361
Palli SR, Kamble PS, Chen H, . Persistence of stimulants in children and adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2012;22(2):139–48. PMID: 22364400.22364400
Park JH, Lee SI and Schachar RJ. Reliability and validity of the child and adolescent functioning impairment scale in children with attention-deficit/hyperactivity disorder. Psychiatry Investig. 2011;8(2):113–22. PMID: 21852987.21852987
Parker A and Corkum P. ADHD Diagnosis: As Simple As Administering a Questionnaire or a Complex Diagnostic Process?. J Atten Disord. 2013. PMID: 23887860.23887860
Pearson DA, Santos CW, Aman MG, . Effects of extended release methylphenidate treatment on ratings of attention-deficit/hyperactivity disorder (ADHD) and associated behavior in children with autism spectrum disorders and ADHD symptoms. J Child Adolesc Psychopharmacol. 2013;23(5):337–51. PMID: 23782128.23782128
Penzner JB, Dudas M, Saito E, . Lack of effect of stimulant combination with second-generation antipsychotics on weight gain, metabolic changes, prolactin levels, and sedation in youth with clinically relevant aggression or oppositionality. J Child Adolesc Psychopharmacol. 2009;19(5):563–73. PMID: 19877981.19877981
Pfiffner LJ, Rooney M, Haack L, . A Randomized Controlled Trial of a School-Implemented School–Home Intervention for Attention-Deficit/Hyperactivity Disorder Symptoms and Impairment. Journal of the American Academy of Child and Adolescent Psychiatry. 2016;55(9):762–770.27566117
Prevatt F and Yelland S. An empirical evaluation of ADHD coaching in college students. Journal of Attention Disorders. 2015;19(8):666–677.23509112
Reddy LA, Newman E, Pedigo TK, . Concurrent validity of the pediatric attention disorders diagnostic screener for children with ADHD. Child Neuropsychol. 2010;16(5):478–93. PMID: 20485995.20485995
Redmond SM, Thompson HL and Goldstein S. Psycholinguistic profiling differentiates specific language impairment from typical development and from attention-deficit/hyperactivity disorder. J Speech Lang Hear Res. 2011;54(1):99–117. PMID: 20719871.20719871
Reimherr FW, Marchant BK, Olsen JL, . Oppositional defiant disorder in adults with ADHD. J Atten Disord. 2013;17(2):102–13. PMID: 22100691.22100691
Renes JS, de Ridder MA, Breukhoven PE, . Methylphenidate and the response to growth hormone treatment in short children born small for gestational age. PLoS One. 2012;7(12):e53164. PMID: 23300884.23300884
Richa S, Rohayem J, Chammai R, . ADHD prevalence in Lebanese school-age population. J Atten Disord. 2014;18(3):242–6. PMID: 22628148.22628148
Roberts G, Rane S, Fall A-M, . The impact of intensive reading intervention on level of attention in middle school students. Journal of Clinical Child and Adolescent Psychology. 2015;44(6):942–953.24885289
Rogalin MT and Nencini A. Consequences of the ‘Attention-Deficit/Hyperactivity Disorder’ (ADHD) diagnosis. An investigation with education professionals. Psychological Studies. 2015;60(1):41–49.
Rogińska N and Bieganowska K. Sick sinus syndrome: A family study. Cardiology in the Young. 2014;24(1):136–139.24020943
Rohatgi RK, Bos JM and Ackerman MJ. Stimulant therapy in children with attention-deficit/hyperactivity disorder and concomitant long QT syndrome: A safe combination?. Heart Rhythm. 2015;12(8):1807–12. PMID: 25956966.25956966
Rose SR, Reeves G, Gut R, . Attention-Deficit/Hyperactivity Disorder Medication Treatment Impact on Response to Growth Hormone Therapy: Results from the ANSWER Program, a Non-Interventional Study. Journal of Pediatrics. 2015.
Rotger S, Richarte V, Nogueira M, . Functioning Assessment Short Test (FAST): validity and reliability in adults with attention-deficit/hyperactivity disorder. Eur Arch Psychiatry Clin Neurosci. 2014;264(8):719–27. PMID: 24710954.24710954
Rubio B, Hernandez S, Verche E, . A pilot study: differential effects of methylphenidate-OROS on working memory and attention functions in children with attention-deficit/hyperactivity disorder with and without behavioural comorbidities. Atten Defic Hyperact Disord. 2011;3(1):13–20. PMID: 21432614.21432614
Rucklidge JJ, Frampton CM, Gorman B, . Vitamin–mineral treatment of attention-deficit hyperactivity disorder in adults: Double-blind randomised placebo-controlled trial. The British Journal of Psychiatry. 2014;204(4):306–315.24482441
Rucklidge JJ, Johnstone J, Gorman B, . Moderators of treatment response in adults with ADHD treated with a vitamin-mineral supplement. Prog Neuropsychopharmacol Biol Psychiatry. 2014;50:163–71. PMID: 24374068.24374068
Russ SA, Larson K and Halfon N. A national profile of childhood epilepsy and seizure disorder. Pediatrics. 2012;129(2):256–64. PMID: 22271699.22271699
Sable JJ, Kyle MR, Knopf KL, . The Sensory Gating Inventory as a potential diagnostic tool for attention-deficit hyperactivity disorder. Atten Defic Hyperact Disord. 2012;4(3):141–4. PMID: 22644992.22644992
Sasane R, Hodgkins P and Meijer W. Treatment stabilization in children and adolescents with attention-deficit/hyperactivity disorder: data from the Netherlands. Curr Med Res Opin. 2010;26(11):2565–74. PMID: 20863165.20863165
Sayal K, Merrell C, Tymms P, . Academic Outcomes Following a School-Based RCT for ADHD: 6-Year Follow-Up. J Atten Disord. 2015. PMID: 25555626.25555626
Sayal K, Taylor JA, Valentine A, . Effectiveness and cost-effectiveness of a brief school-based group programme for parents of children at risk of ADHD: a cluster randomised controlled trial. Child Care Health Dev. 2016;42(4):521–33. PMID: 27272608.27272608
Scahill L, McCracken JT, King BH, . Extended-Release Guanfacine for Hyperactivity in Children With Autism Spectrum Disorder. Am J Psychiatry. 2015. PMID: 26315981.26315981
Scheithauer MC and Kelley ML. Self-Monitoring by College Students With ADHD: The Impact on Academic Performance. J Atten Disord. 2014. PMID: 25319163.25319163
Schneider H, Thornton JF, Freeman MA, . Conventional SPECT versus 3D thresholded SPECT imaging in the diagnosis of ADHD: A retrospective study. Journal of Neuropsychiatry and Clinical Neurosciences. 2014;26(4):335–343.26037855
Setyawan J, Guerin A, Hodgkins P, . Treatment persistence in attention deficit/hyperactivity disorder: a retrospective analysis of patients initiated on lisdexamfetamine vs other medications. J Med Econ. 2013;16(11):1275–89. PMID: 24004347.24004347
Shata ZN, Abu-Nazel MW, Fahmy SI, . Efficacy of a psychosocial intervention for parents of children with attention deficit hyperactivity disorder, Alexandria, Egypt. J Egypt Public Health Assoc. 2014;89(1):9–15. PMID: 24717395.24717395
Shyu YC, Yuan SS, Lee SY, . Attention-deficit/hyperactivity disorder, methylphenidate use and the risk of developing schizophrenia spectrum disorders: A nationwide population-based study in Taiwan. Schizophr Res. 2015;168(1–2):161–7. PMID: 26363968.26363968
Sikirica V, Xie J, He TL, . Immediate-release versus extended-release guanfacine for treatment of attention-deficit/hyperactivity disorder. American Journal of Pharmacy Benefits. 2013;5(4):e85–e94.
Silverstein M, Hironaka LK, Feinberg E, . Using Clinical Data to Predict Accurate ADHD Diagnoses Among Urban Children. Clin Pediatr (Phila). 2015. PMID: 26130393.26130393
Silverstein M, Hironaka LK, Walter HJ, . Collaborative care for children with ADHD symptoms: a randomized comparative effectiveness trial. Pediatrics. 2015;135(4):e858–67. PMID: 25802346.25802346
Sirois PA, Montepiedra G, Kapetanovic S, . Impact of medications prescribed for treatment of attention-deficit hyperactivity disorder on physical growth in children and adolescents with HIV. J Dev Behav Pediatr. 2009;30(5):403–12. PMID: 19827220.19827220
Smith T, Aman MG, Arnold LE, . Atomoxetine and Parent Training for Children With Autism and Attention-Deficit/Hyperactivity Disorder: A 24-Week Extension Study. J Am Acad Child Adolesc Psychiatry. 2016;55(10):868–876.e2. PMID: 27663942.27663942
Snyder SM, Rugino TA, Hornig M, . Integration of an EEG biomarker with a clinician’s ADHD evaluation. Brain Behav. 2015;5(4):e00330. PMID: 25798338.25798338
Soderstrom S, Pettersson R and Nilsson KW. Quantitative and subjective behavioural aspects in the assessment of attention-deficit hyperactivity disorder (ADHD) in adults. Nord J Psychiatry. 2014;68(1):30–7. PMID: 23527787.23527787
Somuk BT, Bozkurt H, Goktas G, . Impact of adenotonsillectomy on ADHD and nocturnal enuresis in children with chronic adenotonsillar hypertrophy. Am J Otolaryngol. 2016;37(1):27–30. PMID: 26700255.26700255
Stattin H, Enebrink P, Ozdemir M, . A National Evaluation of Parenting Programs in Sweden: The Short-Term Effects Using an RCT Effectiveness Design. J Consult Clin Psychol. 2015. PMID: 26009784.26009784
Steiner NJ, Frenette E, Hynes C, . A pilot feasibility study of neurofeedback for children with autism. Applied Psychophysiology and Biofeedback. 2014;39(2):99–107. PMID: 2014-14168-001.24737038
Thakur GA, Grizenko N, Sengupta SM, . The 5-HTTLPR polymorphism of the serotonin transporter gene and short term behavioral response to methylphenidate in children with ADHD. BMC Psychiatry. 2010;10:50. PMID: 20569447.20569447
Toomey SL, Chan E, Ratner JA, . The patient-centered medical home, practice patterns, and functional outcomes for children with attention deficit/hyperactivity disorder. Acad Pediatr. 2011;11(6):500–7. PMID: 21967721.21967721
Trillingsgaard T, Trillingsgaard A and Webster-Stratton C. Assessing the effectiveness of the ‘Incredible Years((R)) parent training’ to parents of young children with ADHD symptoms - a preliminary report. Scand J Psychol. 2014;55(6):538–45. PMID: 25130208.25130208
Ullebo AK, Posserud MB, Heiervang E, . Screening for the attention deficit hyperactivity disorder phenotype using the strength and difficulties questionnaire. Eur Child Adolesc Psychiatry. 2011;20(9):451–8. PMID: 21833627.21833627
Valo S and Tannock R. Diagnostic instability of DSM-IV ADHD subtypes: effects of informant source, instrumentation, and methods for combining symptom reports. J Clin Child Adolesc Psychol. 2010;39(6):749–60. PMID: 21058123.21058123
Villodas MT, McBurnett K, Kaiser N, . Additive effects of parent adherence on social and behavioral outcomes of a collaborative school–home behavioral intervention for ADHD. Child Psychiatry and Human Development. 2014;45(3):348–360. PMID: 2013-33475-001.24043560
Vogel T, Dom G, van de Glind G, . Is attention deficit/hyperactivity disorder among men associated with initiation or escalation of substance use at 15-month follow up? A longitudinal study involving young Swiss men. Addiction. 2016. PMID: 27061514.27061514
Wakschlag LS, Estabrook R, Petitclerc A, . Clinical Implications of a Dimensional Approach: The Normal:Abnormal Spectrum of Early Irritability. J Am Acad Child Adolesc Psychiatry. 2015;54(8):626–34. PMID: 26210331.26210331
Wang LJ, Shyu YC, Yuan SS, . Attention-deficit hyperactivity disorder, its pharmacotherapy, and the risk of developing bipolar disorder: A nationwide population-based study in Taiwan. Journal of Psychiatric Research. 2016;72:6–14.26519764
Whiteley P, Haracopos D, Knivsberg AM, . The ScanBrit randomised, controlled, single-blind study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders. Nutr Neurosci. 2010;13(2):87–100. PMID: 20406576.20406576
Williamson KD, Combs HL, Berry DT, . Discriminating among ADHD alone, ADHD with a comorbid psychological disorder, and feigned ADHD in a college sample. Clin Neuropsychol. 2014;28(7):1182–96. PMID: 25225947.25225947
Winterstein AG, Gerhard T, Shuster J, . Cardiac safety of methylphenidate versus amphetamine salts in the treatment of ADHD. Pediatrics. 2009;124(1):e75–80. PMID: 19564272.19564272
Yang HN, Tai YM, Yang LK, . Prediction of childhood ADHD symptoms to quality of life in young adults: adult ADHD and anxiety/depression as mediators. Res Dev Disabil. 2013;34(10):3168–81. PMID: 23886759.23886759
Young JC and Gross AM. Detection of response bias and noncredible performance in adult attention-deficit/hyperactivity disorder. Arch Clin Neuropsychol. 2011;26(3):165–75. PMID: 21441258.21441258
Zambrano-Sanchez E, Martinez-Cortes JA, Del Rio-Carlos Y, . Identification of attention-deficit-hyperactivity disorder and conduct disorder in Mexican children by the scale for evaluation of deficit of attention and hyperactivity. Psychiatry Res. 2011;187(3):437–40. PMID: 20934222.20934222
Zentall SS and Lee J. A Reading Motivation Intervention With Differential Outcomes for Students At Risk for Reading Disabilities, ADHD, and Typical Comparisons: “Clever Is and Clever Does”. Learning Disability Quarterly. 2012;35(4):248–259.
Zhang C, Kutyifa V, Moss AJ, . Long-QT Syndrome and Therapy for Attention Deficit/Hyperactivity Disorder. Journal of Cardiovascular Electrophysiology. 2015;26(10):1039–1044.26149510
Zoega H, Rothman KJ, Huybrechts KF, . A population-based study of stimulant drug treatment of ADHD and academic progress in children. Pediatrics. 2012;130(1):e53–62. PMID: 22732167.22732167
Zoega H, Valdimarsdottir UA and Hernandez-Diaz S. Age, academic performance, and stimulant prescribing for ADHD: a nationwide cohort study. Pediatrics. 2012;130(6):1012–8. PMID: 23166340.23166340
Zuvekas SH and Vitiello B. Stimulant medication use in children: a 12-year perspective. Am J Psychiatry. 2012;169(2):160–6. PMID: 22420039.22420039

### Does Not Include an Intervention of Interest

Bachmann M, Bachmann CJ, John K, . The effectiveness of child and adolescent psychiatric treatments in a naturalistic outpatient setting. World Psychiatry. 2010;9(2):111–7. PMID: 20671900.20671900
Barnard-Brak L, Schmidt M and Sulak T. ADHD medication vacations and parent-child interactions by gender. J Atten Disord. 2013;17(6):506–9. PMID: 22366239.22366239
Bart O, Raz S and Dan O. Reliability and validity of the Continuous Performance Test among children. Assessment. 2014;21(5):637–643. PMID: 2014-39289-010.24752387
Bauer NS, Szczepaniak D, Sullivan PD, . Group Visits to Improve Pediatric Attention-Deficit Hyperactivity Disorder Chronic Care Management. J Dev Behav Pediatr. 2015;36(8):553–61. PMID: 26414089.26414089
Biederman J, Monuteaux MC, Spencer T, . Do stimulants protect against psychiatric disorders in youth with ADHD? A 10-year follow-up study. Pediatrics. 2009;124(1):71–8. PMID: 19564285.19564285
Biederman J, Petty CR, Fried R, . Is the diagnosis of ADHD influenced by time of entry to school? An examination of clinical, familial, and functional correlates in children at early and late entry points. J Atten Disord. 2014;18(3):179–85. PMID: 22628145.22628145
Brocki KC, Eninger L, Thorell LB, . Interrelations between executive function and symptoms of hyperactivity/impulsivity and inattention in preschoolers: a two year longitudinal study. J Abnorm Child Psychol. 2010;38(2):163–71. PMID: 19763816.19763816
Carroll AE, Bauer NS, Dugan TM, . Use of a computerized decision aid for ADHD diagnosis: a randomized controlled trial. Pediatrics. 2013;132(3):e623–9. PMID: 23958768.23958768
Casagrande M, Martella D, Ruggiero MC, . Assessing attentional systems in children with Attention Deficit Hyperactivity Disorder. Arch Clin Neuropsychol. 2012;27(1):30–44. PMID: 22071484.22071484
Casaseca-de-la-Higuera P, Martin-Martinez D, Alberola-Lopez S, . Automatic diagnosis of ADHD based on multichannel nonlinear analysis of actimetry registries. Conf Proc IEEE Eng Med Biol Soc. 2012;2012:4204–7. PMID: 23366855.23366855
Catale C, Geurten M, Lejeune C, . The Conners Parent Rating Scale: Psychometric properties in typically developing 4- to 12-year-old Belgian French-speaking children. European Review of Applied Psychology/Revue Européenne de Psychologie Appliquée. 2014;64(5):221–227. PMID: 2014-42090-003.
Chilakamarri JK, Filkowski MM and Ghaemi SN. Misdiagnosis of bipolar disorder in children and adolescents: a comparison with ADHD and major depressive disorder. Ann Clin Psychiatry. 2011;23(1):25–9. PMID: 21318193.21318193
Cordier R, Bundy A, Hocking C, . Comparison of the play of children with attention deficit hyperactivity disorder by subtypes. Aust Occup Ther J. 2010;57(2):137–45. PMID: 20854579.20854579
de Luis-Garcia R, Cabus-Pinol G, Imaz-Roncero C, . Attention deficit/hyperactivity disorder and medication with stimulants in young children: a DTI study. Prog Neuropsychopharmacol Biol Psychiatry. 2015;57:176–84. PMID: 25445066.25445066
Demidovich M, Kolko DJ, Bukstein OG, . Medication refusal in children with oppositional defiant disorder or conduct disorder and comorbid attention-deficit/hyperactivity disorder: medication history and clinical correlates. J Child Adolesc Psychopharmacol. 2011;21(1):57–66. PMID: 21288119.21288119
Denis I, Guay MC, Foldes-Busque G, . Effect of Treating Anxiety Disorders on Cognitive Deficits and Behaviors Associated with Attention Deficit Hyperactivity Disorder: A Preliminary Study. Child Psychiatry Hum Dev. 2015. PMID: 26323585.26323585
Dyck MJ and Piek JP. Developmental delays in children with ADHD. J Atten Disord. 2014;18(5):466–78. PMID: 22508756.22508756
Efron D and Sciberras E. The diagnostic outcomes of children with suspected attention deficit hyperactivity disorder following multidisciplinary assessment. J Paediatr Child Health. 2010;46(7–8):392–7. PMID: 20546102.20546102
England SJ, Picchietti DL, Couvadelli BV, . L-Dopa improves Restless Legs Syndrome and periodic limb movements in sleep but not Attention-Deficit-Hyperactivity Disorder in a double-blind trial in children. Sleep Med. 2011;12(5):471–7. PMID: 21463967.21463967
Fabiano GA, Schatz NK, Morris KL, . Efficacy of a Family-Focused Intervention for Young Drivers With Attention-Deficit Hyperactivity Disorder. J Consult Clin Psychol. 2016. PMID: 27618640.27618640
Farmer CA, Epstein JN, Findling RL, . Risperidone Added to Psychostimulant in Children with Severe Aggression and Attention-Deficit/Hyperactivity Disorder: Lack of Effect on Attention and Short-Term Memory. J Child Adolesc Psychopharmacol. 2016. PMID: 27348211.27348211
Fergusson DM, Boden JM and Horwood LJ. Classification of behavior disorders in adolescence: scaling methods, predictive validity, and gender differences. J Abnorm Psychol. 2010;119(4):699–712. PMID: 20853914.20853914
Fiks AG, Mayne S, Hughes CC, . Development of an instrument to measure parents’ preferences and goals for the treatment of attention deficit-hyperactivity disorder. Acad Pediatr. 2012;12(5):445–55. PMID: 22748759.22748759
Foreman DM and Morton S. Nurse-delivered and doctor-delivered care in an attention deficit hyperactivity disorder follow-up clinic: a comparative study using propensity score matching. J Adv Nurs. 2011;67(6):1341–8. PMID: 21375572.21375572
Fortes D, Serra-Pinheiro MA, Coutinho G, . Quantitative measurement of impairment in ADHD: Perspectives for research and clinical practice. Revista de Psiquiatria Clinica. 2014;41(5):124–130.
Fujioka T, Takiguchi S, Yatsuga C, . Advanced Test of Attention in Children with Attention-Deficit/Hyperactivity Disorder in Japan for Evaluation of Methylphenidate and Atomoxetine Effects. Clin Psychopharmacol Neurosci. 2016;14(1):79–87. PMID: 26792044.26792044
Goetz M, Yeh CB, Ondrejka I, . A 12-month prospective, observational study of treatment regimen and quality of life associated with ADHD in central and eastern europe and eastern Asia. J Atten Disord. 2012;16(1):44–59. PMID: 20858785.20858785
Groenman AP, Oosterlaan J, Rommelse NN, . Stimulant treatment for attention-deficit hyperactivity disorder and risk of developing substance use disorder. Br J Psychiatry. 2013;203(2):112–9. PMID: 23846996.23846996
Haynes V, Lopez-Romero P and Anand E. Attention-deficit/hyperactivity disorder Under Treatment Outcomes Research (AUTOR): a European observational study in pediatric subjects. Atten Defic Hyperact Disord. 2015;7(4):295–311. PMID: 26115621.26115621
Hechtman L, Swanson JM, Sibley MH, . Functional Adult Outcomes 16 Years After Childhood Diagnosis of Attention-Deficit/Hyperactivity Disorder: MTA Results. Journal of the American Academy of Child and Adolescent Psychiatry. 2016.
Hinshaw SP, Owens EB, Zalecki C, . Prospective follow-up of girls with attention-deficit/hyperactivity disorder into early adulthood: continuing impairment includes elevated risk for suicide attempts and self-injury. J Consult Clin Psychol. 2012;80(6):1041–51. PMID: 22889337.22889337
Jans T, Jacob C, Warnke A, . Does intensive multimodal treatment for maternal ADHD improve the efficacy of parent training for children with ADHD? A randomized controlled multicenter trial. J Child Psychol Psychiatry. 2015. PMID: 26123832.26123832
Kim HW, Cho SC, Kim BN, . Does oppositional defiant disorder have temperament and psychopathological profiles independent of attention deficit/hyperactivity disorder?. Compr Psychiatry. 2010;51(4):412–8. PMID: 20579516.20579516
Kim JW, Kim BN, Lee J, . Desynchronization of Theta-Phase Gamma-Amplitude Coupling during a Mental Arithmetic Task in Children with Attention Deficit/Hyperactivity Disorder. PLoS One. 2016;11(3):e0145288. PMID: 26930194.26930194
Kolko DJ and Pardini DA. ODD dimensions, ADHD, and callous-unemotional traits as predictors of treatment response in children with disruptive behavior disorders. J Abnorm Psychol. 2010;119(4):713–25. PMID: 21090875.21090875
Kurth L and Haussmann R. Perinatal Pitocin as an early ADHD biomarker: neurodevelopmental risk?. J Atten Disord. 2011;15(5):423–31. PMID: 21527574.21527574
Lahey BB and Willcutt EG. Predictive validity of a continuous alternative to nominal subtypes of attention-deficit/hyperactivity disorder for DSM-V. J Clin Child Adolesc Psychol. 2010;39(6):761–75. PMID: 21058124.21058124
Lambek R and Trillingsgaard A. Elaboration, validation and standardization of the five to fifteen (FTF) questionnaire in a Danish population sample. Research in Developmental Disabilities. 2015;38:161–170.25590170
Lavigne JV, Dulcan MK, LeBailly SA, . Computer-assisted management of attention-deficit/hyperactivity disorder. Pediatrics. 2011;128(1):e46–53. PMID: 21669891.21669891
Lin DY, Kratochvil CJ, Xu W, . A randomized trial of edivoxetine in pediatric patients with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2014;24(4):190–200. PMID: 24840045.24840045
Mattis S, Papolos D, Luck D, . Neuropsychological factors differentiating treated children with pediatric bipolar disorder from those with attention-deficit/hyperactivity disorder. J Clin Exp Neuropsychol. 2011;33(1):74–84. PMID: 20603740.20603740
Monden Y, Dan I, Nagashima M, . Individual classification of ADHD children by right prefrontal hemodynamic responses during a go/no-go task as assessed by fNIRS. Neuroimage Clin. 2015;9:1–12. PMID: 26266096.26266096
Montoya A, Escobar R, Garcia-Polavieja MJ, . Changes of urine dihydroxyphenylglycol to norepinephrine ratio in children with attention-deficit hyperactivity disorder (ADHD) treated with atomoxetine. J Child Neurol. 2011;26(1):31–6. PMID: 20525942.20525942
Montoya A, Hervas A, Fuentes J, . Cluster-randomized, controlled 12-month trial to evaluate the effect of a parental psychoeducation program on medication persistence in children with attention-deficit/hyperactivity disorder. Neuropsychiatr Dis Treat. 2014;10:1081–92. PMID: 24966679.24966679
Morrow RL, Garland EJ, Wright JM, . Influence of relative age on diagnosis and treatment of attention-deficit/hyperactivity disorder in children. Cmaj. 2012;184(7):755–62. PMID: 22392937.22392937
Mukherjee S, Aneja S, Russell PS, . INCLEN diagnostic tool for attention deficit hyperactivity disorder (INDT-ADHD): development and validation. Indian Pediatr. 2014;51(6):457–62. PMID: 24986281.24986281
O’Connor B, Garner AA, Peugh JL, . Improved but still impaired: Symptom-impairment correspondence among youth with attention-deficit hyperactivity disorder receiving community-based care. Journal of Developmental and Behavioral Pediatrics. 2015;36(2):106–114.25650953
Park JI, Shim SH, Lee M, . The validities and efficiencies of korean ADHD rating scale and korean child behavior checklist for screening children with ADHD in the community. Psychiatry Investig. 2014;11(3):258–65. PMID: 25110498.25110498
Paul-Jordanov I, Bechtold M and Gawrilow C. Methylphenidate and if-then plans are comparable in modulating the P300 and increasing response inhibition in children with ADHD. Atten Defic Hyperact Disord. 2010;2(3):115–26. PMID: 21432597.21432597
Pedersen SL, Walther CA, Harty SC, . The Indirect Effects of Childhood ADHD on Alcohol Problems in Adulthood through Unique Facets of Impulsivity. Addiction. 2016. PMID: 26999438.26999438
Peterson BS, Potenza MN, Wang Z, . An FMRI study of the effects of psychostimulants on default-mode processing during Stroop task performance in youths with ADHD. Am J Psychiatry. 2009;166(11):1286–94. PMID: 19755575.19755575
Powell SG, Thomsen PH, Frydenberg M, . Long-term treatment of ADHD with stimulants: a large observational study of real-life patients. J Atten Disord. 2011;15(6):439–51. PMID: 20631198.20631198
Riahi F, Tashakori A and Abdi L. Comparison between the efficacies of Risperidone with Haloperidol in the treatment of attention-deficit hyperactivity disorder (ADHD) among preschoolers: a randomized double-blind clinical trial. Electron Physician. 2016;8(9):2840–2848. PMID: 27790334.27790334
Riddle MA, Yershova K, Lazzaretto D, . The Preschool Attention-Deficit/Hyperactivity Disorder Treatment Study (PATS) 6-year follow-up. J Am Acad Child Adolesc Psychiatry. 2013;52(3):264–278.e2. PMID: 23452683.23452683
Salardini E, Zeinoddini A, Kohi A, . Agomelatine as a Treatment for Attention-Deficit/Hyperactivity Disorder in Children and Adolescents: A Double-Blind, Randomized Clinical Trial. J Child Adolesc Psychopharmacol. 2016. PMID: 27286139.27286139
Sallee FR. Early Morning Functioning in Stimulant-Treated Children and Adolescents with Attention-Deficit/Hyperactivity Disorder, and its Impact on Caregivers. Journal of Child and Adolescent Psychopharmacology. 2015;25(7):558–565.26151738
Sandler AD, Glesne CE and Bodfish JW. Conditioned placebo dose reduction: a new treatment in attention-deficit hyperactivity disorder?. J Dev Behav Pediatr. 2010;31(5):369–75. PMID: 20495473.20495473
Sangal RB, Blumer JL, Lankford DA, . Eszopiclone for insomnia associated with attention-deficit/hyperactivity disorder. Pediatrics. 2014;134(4):e1095–103. PMID: 25266438.25266438
Serrano E, Ezpeleta L, Alda JA, . Psychometric properties of the Young Mania Rating Scale for the identification of mania symptoms in Spanish children and adolescents with attention deficit/hyperactivity disorder. Psychopathology. 2011;44(2):125–32. PMID: 21228617.21228617
Sibley MH, Pelham WE, Jr., Molina BS, . Diagnosing ADHD in adolescence. J Consult Clin Psychol. 2012;80(1):139–50. PMID: 22148878.22148878
Sims DM and Lonigan CJ. Multi-method assessment of ADHD characteristics in preschool children: Relations between measures. Early Childhood Research Quarterly. 2012;27(2):329–337.22518069
Solanto MV and Alvir J. Reliability of DSM-IV Symptom Ratings of ADHD: implications for DSM-V. J Atten Disord. 2009;13(2):107–16. PMID: 19372494.19372494
Sonuga-Barke EJ, Coghill D, DeBacker M, . Measuring methylphenidate response in attention-deficit/hyperactvity disorder: how are laboratory classroom-based measures related to parent ratings?. J Child Adolesc Psychopharmacol. 2009;19(6):691–8. PMID: 20035587.20035587
Srebnicki T, Kolakowski A and Wolanczyk T. Adolescent outcome of child ADHD in primary care setting: stability of diagnosis. J Atten Disord. 2013;17(8):655–9. PMID: 22408135.22408135
Staikova E, Marks DJ, Miller CJ, . Childhood stimulant treatment and teen depression: is there a relationship?. J Child Adolesc Psychopharmacol. 2010;20(5):387–93. PMID: 20973709.20973709
Stocks JD, Taneja BK, Baroldi P, . A phase 2a randomized, parallel group, dose-ranging study of molindone in children with attention-deficit/hyperactivity disorder and persistent, serious conduct problems. J Child Adolesc Psychopharmacol. 2012;22(2):102–11. PMID: 22372512.22372512
Szomlaiski N, Dyrborg J, Rasmussen H, . Validity and clinical feasibility of the ADHD rating scale (ADHD-RS) A Danish Nationwide Multicenter Study. Acta Paediatr. 2009;98(2):397–402. PMID: 18775056.18775056
Telford C, Green C, Logan S, . Estimating the costs of ongoing care for adolescents with attention-deficit hyperactivity disorder. Soc Psychiatry Psychiatr Epidemiol. 2013;48(2):337–44. PMID: 22699685.22699685
Tzang RF, Chang YC, Tsai GE, . Sarcosine treatment for oppositional defiant disorder symptoms of attention deficit hyperactivity disorder children. J Psychopharmacol. 2016. PMID: 27443598.27443598
Vitiello B, Lazzaretto D, Yershova K, . Pharmacotherapy of the Preschool ADHD Treatment Study (PATS) Children Growing Up. J Am Acad Child Adolesc Psychiatry. 2015;54(7):550–6. PMID: 26088659.26088659
Vollebregt MA, Van Dongen-Boomsma M, Slaats-Willemse D, . How the Individual Alpha Peak Frequency Helps Unravel the Neurophysiologic Underpinnings of Behavioral Functioning in Children With Attention-Deficit/Hyperactivity Disorder. Clinical EEG and Neuroscience. 2015;46(4):285–291.25392007
Volpe RJ, DuPaul GJ, Jitendra AK, . Consultation-based academic interventions for children with attention deficit hyperactivity disorder: Effects on reading and mathematics outcomes at 1-year follow-up. School Psychology Review. 2009;38(1):5–13.
Volpe RJ, Gadow KD, Blom-Hoffman J, . Factor-analytic and individualized approaches to constructing brief measures of ADHD behaviors. Journal of Emotional and Behavioral Disorders. 2009;17(2):118–128.
Wan Salwina WI, Baharudin A, Nik Ruzyanei NJ, . Attention deficit hyperactivity disorder symptoms reporting in Malaysian adolescents: do adolescents, parents and teachers agree with each other?. Asian J Psychiatr. 2013;6(6):483–7. PMID: 24309858.24309858
Waxmonsky JG, Waschbusch DA, Belin P, . A Randomized Clinical Trial of an Integrative Group Therapy for Children With Severe Mood Dysregulation. J Am Acad Child Adolesc Psychiatry. 2016;55(3):196–207. PMID: 26903253.26903253
Wehmeier PM, Schacht A, Dittmann RW, . Minor differences in ADHD-related difficulties between boys and girls treated with atomoxetine for attention-deficit/hyperactivity disorder. Atten Defic Hyperact Disord. 2010;2(2):73–85. PMID: 21432592.21432592
Westerlund J, Ek U, Holmberg K, . The Conners’ 10-item scale: findings in a total population of Swedish 10–11-year-old children. Acta Paediatr. 2009;98(5):828–33. PMID: 19154524.19154524
Winters KC, Lee S, Botzet A, . A Prospective Examination of the Association of Stimulant Medication History and Drug Use Outcomes among Community Samples of ADHD Youths. J Child Adolesc Subst Abuse. 2011;20(4):314–329. PMID: 22582022.22582022
Wu SH, Wang K, Chen Y, .Exploratory analysis of early treatment discontinuation and clinical outcomes of patients with attention-deficit/hyperactivity disorder. Asia-Pacific Psychiatry. 2015.
Zima BT, Bussing R, Tang L, . Quality of care for childhood attention-deficit/hyperactivity disorder in a managed care medicaid program. J Am Acad Child Adolesc Psychiatry. 2010;49(12):1225–37, 1237.e1–11. PMID: 21093772.21093772

### Does Not Include a Comparator of Interest

Adler LA, Shaw DM, Spencer TJ, . Preliminary examination of the reliability and concurrent validity of the attention-deficit/hyperactivity disorder self-report scale v1.1 symptom checklist to rate symptoms of attention-deficit/hyperactivity disorder in adolescents. J Child Adolesc Psychopharmacol. 2012;22(3):238–44. PMID: 22537184.22537184
al Ansari A and Asiri MM. The impact of multimodal psychosocial intervention among children with attention deficit hyperactivity disorder. Bahrain Medical Bulletin. 2012;34(1):1–6.
Alloway TP, Gathercole SE, Holmes J, . The diagnostic utility of behavioral checklists in identifying children with ADHD and children with working memory deficits. Child Psychiatry Hum Dev. 2009;40(3):353–66. PMID: 19280339.19280339
Amonn F, Frölich J, Breuer D, . Evaluation of a computer-based neuropsychological training in children with Attention-Deficit Hyperactivity Disorder (ADHD). NeuroRehabilitation. 2013;32(3):555–562.23648609
An L, Cao XH, Cao QJ, . Methylphenidate normalizes resting-state brain dysfunction in boys with attention deficit hyperactivity disorder. Neuropsychopharmacology. 2013;38(7):1287–95. PMID: 23340519.23340519
Araki A, Ikegami M, Okayama A, . Improved prefrontal activity in AD/HD children treated with atomoxetine: a NIRS study. Brain Dev. 2015;37(1):76–87. PMID: 24767548.24767548
Arnold LE, Bozzolo DR, Hodgkins P, . Switching from oral extended-release methylphenidate to the methylphenidate transdermal system: continued attention-deficit/hyperactivity disorder symptom control and tolerability after abrupt conversion. Curr Med Res Opin. 2010;26(1):129–37. PMID: 19916704.19916704
Arns M, Drinkenburg W and Leon Kenemans J. The effects of QEEG-informed neurofeedback in ADHD: an open-label pilot study. Appl Psychophysiol Biofeedback. 2012;37(3):171–80. PMID: 22446998.22446998
Atzori P, Usala T, Carucci S, . Predictive factors for persistent use and compliance of immediate-release methylphenidate: a 36-month naturalistic study. J Child Adolesc Psychopharmacol. 2009;19(6):673–81. PMID: 20035585.20035585
Babinski DE, Pelham WE, Jr., Molina BS, . Late adolescent and young adult outcomes of girls diagnosed with ADHD in childhood: an exploratory investigation. J Atten Disord. 2011;15(3):204–14. PMID: 20562386.20562386
Balazs J, Dallos G, Kereszteny A, . Methylphenidate treatment and dyskinesia in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2011;21(2):133–8. PMID: 21486166.21486166
Blader JC, Pliszka SR, Kafantaris V, . Prevalence and Treatment Outcomes of Persistent Negative Mood Among Children with Attention-Deficit/Hyperactivity Disorder and Aggressive Behavior. J Child Adolesc Psychopharmacol. 2016;26(2):164–73. PMID: 26745211.26745211
Bos DJ, Oranje B, Veerhoek ES, . Reduced Symptoms of Inattention after Dietary Omega-3 Fatty Acid Supplementation in Boys with and without Attention Deficit/Hyperactivity Disorder. Neuropsychopharmacology. 2015;40(10):2298–306. PMID: 25790022.25790022
Breuer D, Gortz-Dorten A, Rothenberger A, . Assessment of daily profiles of ADHD and ODD symptoms, and symptomatology related to ADHD medication, by parent and teacher ratings. Eur Child Adolesc Psychiatry. 2011;20 Suppl 2:S289–96. PMID: 21901413.21901413
Brossard-Racine M, Shevell M, Snider L, . Persistent handwriting difficulties in children with ADHD after treatment with stimulant medication. Journal of Attention Disorders. 2015;19(7):620–629.23160486
Brule D, Sule L, Landau-Halpern B, . An open-label pilot study of homeopathic treatment of attention deficit hyperactivity disorder in children and youth. Forsch Komplementmed. 2014;21(5):302–9. PMID: 25427521.25427521
Buyck I and Wiersema JR. Resting electroencephalogram in attention deficit hyperactivity disorder: developmental course and diagnostic value. Psychiatry Res. 2014;216(3):391–7. PMID: 24656956.24656956
Chiarenza GA, Chabot R, Isenhart R, . The quantified EEG characteristics of responders and non-responders to long-term treatment with atomoxetine in children with attention deficit hyperactivity disorders. International Journal of Psychophysiology. 2016;104:44–52.27108364
Childress AC, Cutler AJ, Saylor K, . Participant-perceived quality of life in a long-term, open-label trial of lisdexamfetamine dimesylate in adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2014;24(4):210–7. PMID: 24815910.24815910
Chou WJ, Chen SJ, Chen YS, . Remission in children and adolescents diagnosed with attention-deficit/hyperactivity disorder via an effective and tolerable titration scheme for osmotic release oral system methylphenidate. J Child Adolesc Psychopharmacol. 2012;22(3):215–25. PMID: 22537358.22537358
Ciesielski HA, Tamm L, Vaughn AJ, . Academic Skills Groups for Middle School Children With ADHD in the Outpatient Mental Health Setting: An Open Trial. J Atten Disord. 2015. PMID: 25926629.25926629
Cronin SD, Gottschlich MM, Gose LM, . Zolpidem and Sleep in Pediatric Burn Patients with Attention Deficit/Hyperactivity Disorder. Pediatr Nurs. 2015;41(3):132–4, 140. PMID: 26201171.26201171
Dalsgaard S, Mortensen PB, Frydenberg M, . ADHD, stimulant treatment in childhood and subsequent substance abuse in adulthood - a naturalistic long-term follow-up study. Addict Behav. 2014;39(1):325–8. PMID: 24090624.24090624
Dave UP, Dingankar SR, Saxena VS, . An open-label study to elucidate the effects of standardized Bacopa monnieri extract in the management of symptoms of attention-deficit hyperactivity disorder in children. Adv Mind Body Med. 2014;28(2):10–5. PMID: 24682000.24682000
Davis C, Cohen A, Davids M, . Attention- deficit/hyperactivity disorder in relation to addictive behaviors: A moderated-mediation analysis of personality risk factors and sex. Frontiers in Psychiatry. 2015;6(MAR).
Diaz-Orueta U, Garcia-Lopez C, Crespo-Eguilaz N, . AULA virtual reality test as an attention measure: convergent validity with Conners’ Continuous Performance Test. Child Neuropsychol. 2014;20(3):328–42. PMID: 23638628.23638628
Dittmann RW, Banaschewski T, Schacht A, . Findings from the observational COMPLY study in children and adolescents with ADHD: core symptoms, ADHD-related difficulties, and patients’ emotional expression during psychostimulant or nonstimulant ADHD treatment. Atten Defic Hyperact Disord. 2014;6(4):291–302. PMID: 24705867.24705867
Dittmann RW, Wehmeier PM, Schacht A, . Atomoxetine treatment and ADHD-related difficulties as assessed by adolescent patients, their parents and physicians. Child Adolesc Psychiatry Ment Health. 2009;3(1):21. PMID: 19703299.19703299
Dittmann RW, Wehmeier PM, Schacht A, . Self-esteem in adolescent patients with attention-deficit/hyperactivity disorder during open-label atomoxetine treatment: psychometric evaluation of the Rosenberg Self-Esteem Scale and clinical findings. Atten Defic Hyperact Disord. 2009;1(2):187–200. PMID: 20234829.20234829
Dopfner M, Breuer D, Walter D, . An observational study of once-daily modified-release methylphenidate in ADHD: the effect of previous treatment on ADHD symptoms, other externalising symptoms and quality-of-life outcomes. Eur Child Adolesc Psychiatry. 2011;20(Suppl 2):S277–88. PMID: 21901414.21901414
Döpfner M, Görtz-Dorten A, Breuer D, . An observational study of once-daily modified-release methylphenidate in ADHD: Effectiveness on symptoms and impairment, and safety. European Child & Adolescent Psychiatry. 2011;20(Suppl 2):S243–S255.21901417
Dupuy FE, Clarke AR, Barry RJ, . EEG differences between the Combined and Inattentive types of attention-deficit/hyperactivity disorder in girls: A further investigation. Clinical EEG and Neuroscience. 2014;45(4):231–237.24131620
Dura-Trave T and Gallinas-Victoriano F. Caloric and nutrient intake in children with attention deficit hyperactivity disorder treated with extended-release methylphenidate: analysis of a cross-sectional nutrition survey. JRSM Open. 2014;5(2):2042533313517690. PMID: 25057372.25057372
Dura-Trave T, Yoldi-Petri ME, Gallinas-Victoriano F, . Effects of osmotic-release methylphenidate on height and weight in children with attention-deficit hyperactivity disorder (ADHD) following up to four years of treatment. J Child Neurol. 2012;27(5):604–9. PMID: 22190507.22190507
Efron D, Lycett K and Sciberras E. Use of sleep medication in children with ADHD. Sleep Med. 2014;15(4):472–5. PMID: 24684977.24684977
Epstein JN, Langberg JM, Lichtenstein PK, . Attention-deficit/hyperactivity disorder outcomes for children treated in community-based pediatric settings. Arch Pediatr Adolesc Med. 2010;164(2):160–5. PMID: 20124145.20124145
Ercan ES, Akyol Ardic U, Kabukcu Basay B, . Atomoxetine response in the inattentive and combined subtypes of attention deficit hyperactivity disorder: a retrospective chart review. Atten Defic Hyperact Disord. 2013;5(4):377–85. PMID: 23737214.23737214
Escolano C, Navarro-Gil M, Garcia-Campayo J, . The effects of individual upper alpha neurofeedback in ADHD: an open-label pilot study. Appl Psychophysiol Biofeedback. 2014;39(3–4):193–202. PMID: 25199660.25199660
Faraone SV, Hammerness PG and Wilens TE. Reliability and Validity of the Before-School Functioning Scale in Children With ADHD. J Atten Disord. 2015. PMID: 25575616.25575616
Faraone SV, Spencer TJ, Kollins SH, . Effects of lisdexamfetamine dimesylate treatment for ADHD on growth. J Am Acad Child Adolesc Psychiatry. 2010;49(1):24–32. PMID: 20215923.20215923
Fernandez-Jaen A, Fernandez-Mayoralas DM, Calleja Perez B, . Atomoxetine for attention deficit hyperactivity disorder in mental retardation. Pediatr Neurol. 2010;43(5):341–7. PMID: 20933178.20933178
Fernandez-Jaen A, Fernandez-Mayoralas DM, Calleja-Perez B, . Efficacy of atomoxetine for the treatment of ADHD symptoms in patients with pervasive developmental disorders: a prospective, open-label study. J Atten Disord. 2013;17(6):497–505. PMID: 22366240.22366240
Fernandez-Jaen A, Fernandez-Mayoralas DM, Pardos A, . Clinical and cognitive response to extended-release methylphenidate (Medikinet) in attention deficit/hyperactivity disorder: efficacy evaluation. Adv Ther. 2009;26(12):1097–110. PMID: 20082241.20082241
Findling RL, Cutler AJ, Saylor K, . A long-term open-label safety and effectiveness trial of lisdexamfetamine dimesylate in adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2013;23(1):11–21. PMID: 23410138.23410138
Findling RL, Ginsberg LD, Jain R, . Effectiveness, safety, and tolerability of lisdexamfetamine dimesylate in children with attention-deficit/hyperactivity disorder: an open-label, dose-optimization study. J Child Adolesc Psychopharmacol. 2009;19(6):649–62. PMID: 20035583.20035583
Findling RL, Katic A, Rubin R, . A 6-month, open-label, extension study of the tolerability and effectiveness of the methylphenidate transdermal system in adolescents diagnosed with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2010;20(5):365–75. PMID: 20973707.20973707
Findling RL, Wigal SB, Bukstein OG, . Long-term tolerability of the methylphenidate transdermal system in pediatric attention-deficit/hyperactivity disorder: a multicenter, prospective, 12-month, open-label, uncontrolled, phase III extension of four clinical trials. Clin Ther. 2009;31(8):1844–55. PMID: 19808143.19808143
Ford-Jones PC. Misdiagnosis of attention deficit hyperactivity disorder: ‘Normal behaviour’ and relative maturity. Paediatr Child Health. 2015;20(4):200–2. PMID: 26038639.26038639
Frazier TW, Weiss M, Hodgkins P, . Time course and predictors of health-related quality of life improvement and medication satisfaction in children diagnosed with attention-deficit/hyperactivity disorder treated with the methylphenidate transdermal system. J Child Adolesc Psychopharmacol. 2010;20(5):355–64. PMID: 20973706.20973706
Froehlich TE, Antonini TN, Brinkman WB, . Mediators of methylphenidate effects on math performance in children with attention-deficit hyperactivity disorder. J Dev Behav Pediatr. 2014;35(2):100–7. PMID: 24509055.24509055
Frölich J, Breuer D, Görtz-Dorten A, . Effects of switching to once-daily modified-release methylphenidate from previous treatment with other psychostimulants in children and adolescents with ADHD: An observational study with clinician, parent, and teacher evaluations. Journal of Clinical Psychopharmacology. 2014;34(1):168–171. PMID: 2014-03584-032.24346749
Fuentes J, Danckaerts M, Cardo E, . Long-term quality-of-life and functioning comparison of atomoxetine versus other standard treatment in pediatric attention-deficit/hyperactivity disorder. J Clin Psychopharmacol. 2013;33(6):766–74. PMID: 23963057.23963057
Gadow KD, Brown NV, Arnold LE, . Severely Aggressive Children Receiving Stimulant Medication Versus Stimulant and Risperidone: 12-Month Follow-Up of the TOSCA Trial. J Am Acad Child Adolesc Psychiatry. 2016;55(6):469–78. PMID: 27238065.27238065
Gerwe M, Stollhoff K, Mossakowski J, . Tolerability and effects of OROS(R) MPH (Concerta (R)) on functioning, severity of disease and quality of life in children and adolescents with ADHD: results from a prospective, non-interventional trial. Atten Defic Hyperact Disord. 2009;1(2):175–86. PMID: 21432582.21432582
Golubchik P, Golubchik L, Sever JM, . The beneficial effect of methylphenidate in ADHD with comorbid separation anxiety. Int Clin Psychopharmacol. 2014;29(5):274–8. PMID: 24743562.24743562
Golubchik P, Sever J and Weizman A. Methylphenidate treatment in children with attention deficit hyperactivity disorder and comorbid social phobia. International Clinical Psychopharmacology. 2014;29(4):212–215.24448460
Gormez V, Avery B and Mann H. Switching from immediate release to sustained release methylphenidate in the treatment of children and adolescents with attention deficit/hyperactivity disorder. Eur Rev Med Pharmacol Sci. 2013;17(17):2345–9. PMID: 24065228.24065228
Grizenko N, Rodrigues Pereira RM and Joober R. Sensitivity of scales to evaluate change in symptomatology with psychostimulants in different ADHD subtypes. J Can Acad Child Adolesc Psychiatry. 2013;22(2):153–8. PMID: 23667362.23667362
Guderjahn L, Gold A, Stadler G, . Self-regulation strategies support children with ADHD to overcome symptom-related behavior in the classroom. Atten Defic Hyperact Disord. 2013;5(4):397–407. PMID: 24062181.24062181
Haertling F, Mueller B and Bilke-Hentsch O. Effectiveness and safety of a long-acting, once-daily, two-phase release formulation of methylphenidate (Ritalin® LA) in school children under daily practice conditions. ADHD Attention Deficit and Hyperactivity Disorders. 2015;7(2):157–164.25346231
Halperin JM, Marks DJ, Bedard AC, . Training executive, attention, and motor skills: a proof-of-concept study in preschool children With ADHD. J Atten Disord. 2013;17(8):711–21. PMID: 22392551.22392551
Hammer R, Tennekoon M, Cooke GE, . Feedback associated with expectation for larger-reward improves visuospatial working memory performances in children with ADHD. Dev Cogn Neurosci. 2015;14:38–49. PMID: 26142072.26142072
Hammerness P, Doyle R, Kotarski M, . Atomoxetine in children with attention-deficit hyperactivity disorder with prior stimulant therapy: a prospective open-label study. Eur Child Adolesc Psychiatry. 2009;18(8):493–8. PMID: 19377865.19377865
Hammerness P, Fried R, Petty C, . Assessment of cognitive domains during treatment with OROS methylphenidate in adolescents with ADHD. Child Neuropsychol. 2014;20(3):319–27. PMID: 23639146.23639146
Hammerness P, Joshi G, Doyle R, . Do stimulants reduce the risk for cigarette smoking in youth with attention-deficit hyperactivity disorder? A prospective, long-term, open-label study of extended-release methylphenidate. J Pediatr. 2013;162(1):22–7.e2. PMID: 22878114.22878114
Hammerness P, Wilens T, Mick E, . Cardiovascular effects of longer-term, high-dose OROS methylphenidate in adolescents with attention deficit hyperactivity disorder. J Pediatr. 2009;155(1):84–9, 89.e1. PMID: 19394037.19394037
Hansen MV, Darling L and Holst H. Safety and Tolerability of Lisdexamfetamine: A Retrospective Cohort Study. CNS Drugs. 2015;29(5):415–23. PMID: 25920467.25920467
Harfterkamp M, Buitelaar JK, Minderaa RB, . Long-term treatment with atomoxetine for attention-deficit/hyperactivity disorder symptoms in children and adolescents with autism spectrum disorder: an open-label extension study. J Child Adolesc Psychopharmacol. 2013;23(3):194–9. PMID: 23578015.23578015
Harstad EB, Weaver AL, Katusic SK, . ADHD, stimulant treatment, and growth: a longitudinal study. Pediatrics. 2014;134(4):e935–44. PMID: 25180281.25180281
Helseth SA, Waschbusch DA, Gnagy EM, . Effects of behavioral and pharmacological therapies on peer reinforcement of deviancy in children with ADHD-only, ADHD and conduct problems, and controls. J Consult Clin Psychol. 2015;83(2):280–92. PMID: 25495357.25495357
Hinz M, Stein A, Neff R, . Treatment of attention deficit hyperactivity disorder with monoamine amino acid precursors and organic caution transporter assay interpretation. Neuropsychiatric Disease and Treatment. 2011;7(1):31–38.21326653
Howard AL, Molina BS, Swanson JM, . Developmental progression to early adult binge drinking and marijuana use from worsening versus stable trajectories of adolescent attention deficit/hyperactivity disorder and delinquency. Addiction. 2015;110(5):784–95. PMID: 25664657.25664657
Ishii-Takahashi A, Takizawa R, Nishimura Y, . Neuroimaging-Aided Prediction of the Effect of Methylphenidate in Children with Attention-Deficit Hyperactivity Disorder: A Randomized Controlled Trial. Neuropsychopharmacology. 2015;40(12):2676–85. PMID: 25936640.25936640
Jang B, Song J, Kim J, . Equine-Assisted Activities and Therapy for Treating Children with Attention-Deficit/Hyperactivity Disorder. J Altern Complement Med. 2015;21(9):546–53. PMID: 26167851.26167851
Javelot H, Glay-Ribau C, Ligier F, . Methylphenidate-risperidone combination in child psychiatry: A retrospective analysis of 44 cases. Ann Pharm Fr. 2014;72(3):164–77. PMID: 24780832.24780832
Jin L, Xu W, Krefetz D, . Clinical outcomes from an open-label study of edivoxetine use in pediatric patients with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2013;23(3):200–7. PMID: 23607409.23607409
Johnston BA, Coghill D, Matthews K, . Predicting methylphenidate response in attention deficit hyperactivity disorder: a preliminary study. J Psychopharmacol. 2015;29(1):24–30. PMID: 25237119.25237119
Kądziela-Olech H. The measurement of the symptoms of ADHD in the NICHQ vanderbilt assessment scale for parent (VADPRS) and for teacher (VADTRS). Psychiatria i Psychologia Kliniczna. 2014;14(4):277–283.
Katic A, Ginsberg L, Jain R, . Clinically relevant changes in emotional expression in children with ADHD treated with lisdexamfetamine dimesylate. J Atten Disord. 2012;16(5):384–97. PMID: 21173426.21173426
Kelly AS, Rudser KD, Dengel DR, . Cardiac autonomic dysfunction and arterial stiffness among children and adolescents with attention deficit hyperactivity disorder treated with stimulants. J Pediatr. 2014;165(4):755–9. PMID: 25015574.25015574
Khajehpiri Z, Mahmoudi-Gharaei J, Faghihi T, . Adverse reactions of Methylphenidate in children with attention deficit-hyperactivity disorder: Report from a referral center. Journal of Research in Pharmacy Practice. 2014;3(4):130–136.25535621
Khodadust N, Jalali AH, Ahmadzad-Asl M, . Comparison of Two brands of Methylphenidate (Stimdate((R)) vs. Ritalin((R))) in Children and Adolescents with Attention Deficit Hyperactivity Disorder: A Double-Blind, Randomized Clinical Trial. Iran J Psychiatry Behav Sci. 2012;6(1):26–32. PMID: 24644466.24644466
Kim E, Cheon KA, Joung YS, . The relationship between symptomatic and functional changes of Korean children and adolescents with attention-deficit/hyperactivity disorder treated with osmotic-controlled release oral delivery system-methylphenidate. Clin Neuropharmacol. 2015;38(1):30–5. PMID: 25580917.25580917
Kim HJ, Yang J and Lee MS. Changes of Heart Rate Variability during Methylphenidate Treatment in Attention-Deficit Hyperactivity Disorder Children: A 12-Week Prospective Study. Yonsei Med J. 2015;56(5):1365–71. PMID: 26256981.26256981
Kim HW, Kim SO, Shon S, . Effect of methylphenidate on height and weight in Korean children and adolescents with attention-deficit/hyperactivity disorder: a retrospective chart review. J Child Adolesc Psychopharmacol. 2014;24(8):448–53. PMID: 25285915.25285915
Kim HW, Yoon IY, Cho SC, . The effect of OROS methylphenidate on the sleep of children with attention-deficit/hyperactivity disorder. Int Clin Psychopharmacol. 2010;25(2):107–15. PMID: 20093941.20093941
Kim SH, Han DH, Lee YS, . Baduk (the game of go) improved cognitive function and brain activity in children with attention deficit hyperactivity disorder. Psychiatry Investigation. 2014;11(2):143–151.24843369
Kobel M, Bechtel N, Weber P, . Effects of methylphenidate on working memory functioning in children with attention deficit/hyperactivity disorder. Eur J Paediatr Neurol. 2009;13(6):516–23. PMID: 19056305.19056305
Kordon A, Stollhoff K, Niederkirchner K, . Exploring the impact of once-daily OROS(R) methylphenidate (MPH) on symptoms and quality of life in children and adolescents with ADHD transitioning from immediate-release MPH. Postgrad Med. 2011;123(5):27–38. PMID: 21904084.21904084
Lambert MC, Reid R, Prosser B, . A Survival Analysis of Psychostimulant Prescriptions in New South Wales from 1990 to 2010. J Child Adolesc Psychopharmacol. 2015;25(6):475–81. PMID: 26218772.26218772
Leisman G, Melillo R, Thum S, . The effect of hemisphere specific remediation strategies on the academic performance outcome of children with ADD/ADHD. Int J Adolesc Med Health. 2010;22(2):275–83. PMID: 21061929.21061929
Liao YC, Guo NW, Lei SH, . Electroencephalogram valid rate in simple reaction time task as an easy index of children’s attention functions. Pediatr Int. 2015;57(5):930–5. PMID: 25925420.25925420
Lim CG, Lee TS, Guan C, . A brain-computer interface based attention training program for treating attention deficit hyperactivity disorder. PLoS One. 2012;7(10):e46692. PMID: 23115630.23115630
Loren RE, Vaughn AJ, Langberg JM, . Effects of an 8-session behavioral parent training group for parents of children with ADHD on child impairment and parenting confidence. J Atten Disord. 2015;19(2):158–66. PMID: 23599209.23599209
Lufi D, Bassin-Savion S and Rubel L. The effect of methylphenidate on sustained attention among adolescents with attention-deficit hyperactivity disorder. Neurocase. 2015;21(6):802–808.25771849
Mahon AD, Woodruff ME, Horn MP, . Effect of stimulant medication use by children with ADHD on heart rate and perceived exertion. Adapt Phys Activ Q. 2012;29(2):151–60. PMID: 22467834.22467834
Malik TA and Tariq N. Parent training in reduction of attention-deficit/hyperactivity disorder and oppositional defiant disorder symptoms in children. Pakistan Journal of Psychological Research. 2014;29(1):151–169.
Manos M, Frazier TW, Landgraf JM, . HRQL and medication satisfaction in children with ADHD treated with the methylphenidate transdermal system. Curr Med Res Opin. 2009;25(12):3001–10. PMID: 19849639.19849639
Masi G, Gagliano A, Siracusano R, . Aripirazole in children with Tourette’s disorder and co-morbid attention-deficit/hyperactivity disorder: A 12-week, open-label, preliminary study. Journal of Child and Adolescent Psychopharmacology. 2012;22(2):120–125.22375853
McCarthy A, Asghar S, Wilens T, . Using a Brief Parent-Report Measure to Track Outcomes for Children and Teens with ADHD. Child Psychiatry Hum Dev. 2015. PMID: 26271346.26271346
Mikolajczyk R, Horn J, Schmedt N, . Injury prevention by medication among children with attention-deficit/hyperactivity disorder: a case-only study. JAMA Pediatr. 2015;169(4):391–5. PMID: 25686215.25686215
Moungnoi P and Maipang P. Long-term effects of short-acting methylphenidate on growth rates of children with attention deficit hyperactivity disorder at Queen Sirikit National Institute of Child Health. J Med Assoc Thai. 2011;94(Suppl 3):S158–63. PMID: 22043770.22043770
Na KS, Lee SI, Hong SD, . Effect of osmotic-release oral system methylphenidate on learning skills in adolescents with attention-deficit/hyperactivity disorder: an open-label study. Int Clin Psychopharmacol. 2013;28(4):184–92. PMID: 23587983.23587983
Nagashima M, Monden Y, Dan I, . Acute neuropharmacological effects of atomoxetine on inhibitory control in ADHD children: a fNIRS study. Neuroimage Clin. 2014;6:192–201. PMID: 25379431.25379431
Nair V and Mahadevan S. Randomised controlled study-efficacy of clonidine versus carbamazepine in children with ADHD. J Trop Pediatr. 2009;55(2):116–21. PMID: 19203986.19203986
Niederkirchner K, Slawik L, Wermelskirchen D, . Transitioning to OROS((R)) methylphenidate from atomoxetine is effective in children and adolescents with ADHD. Expert Rev Neurother. 2011;11(4):499–508. PMID: 21469923.21469923
Park SY, Kim EJ and Cheon KA. Association between 5-HTTLPR Polymorphism and Tics after Treatment with Methylphenidate in Korean Children with Attention-Deficit/Hyperactivity Disorder. Journal of Child and Adolescent Psychopharmacology. 2015;25(8):633–640.26402385
Paton K, Hammond P, Barry E, . Methylphenidate improves some but not all measures of attention, as measured by the TEA-Ch in medication-naive children with ADHD. Child Neuropsychol. 2014;20(3):303–18. PMID: 23639119.23639119
Pfiffner LJ, Villodas M, Kaiser N, . Educational outcomes of a collaborative school-home behavioral intervention for ADHD. Sch Psychol Q. 2013;28(1):25–36. PMID: 23506023.23506023
Piepmeier AT, Shih CH, Whedon M, . The effect of acute exercise on cognitive performance in children with and without ADHD. Journal of Sport and Health Science. 2015;4(1):97–104.
Poil SS, Bollmann S, Ghisleni C, . Age dependent electroencephalographic changes in attention-deficit/hyperactivity disorder (ADHD). Clin Neurophysiol. 2014;125(8):1626–38. PMID: 24582383.24582383
Pollak Y, Shomaly HB, Weiss PL, . Methylphenidate effect in children with ADHD can be measured by an ecologically valid continuous performance test embedded in virtual reality. CNS Spectr. 2010;15(2):125–30. PMID: 20414157.20414157
Poulton AS, Bui Q, Melzer E, . Stimulant medication effects on growth and bone age in children with attention-deficit/hyperactivity disorder: a prospective cohort study. Int Clin Psychopharmacol. 2015. PMID: 26544899.26544899
Poulton AS, Melzer E, Tait PR, . Growth and pubertal development of adolescent boys on stimulant medication for attention deficit hyperactivity disorder. Med J Aust. 2013;198(1):29–32. PMID: 23330767.23330767
Powell SG, Frydenberg M and Thomsen PH. The effects of long-term medication on growth in children and adolescents with ADHD: an observational study of a large cohort of real-life patients. Child Adolesc Psychiatry Ment Health. 2015;9:50. PMID: 26516345.26516345
Radziuk AL, Kieling RR, Santos K, . Methylphenidate improves the quality of life of children and adolescents with ADHD and difficult-to-treat epilepsies. Epilepsy Behav. 2015;46:215–20. PMID: 25940104.25940104
Ramtvedt BE and Sundet K. Relationships between computer-based testing and behavioral ratings in the assessment of attention and activity in a pediatric ADHD stimulant crossover trial. Clin Neuropsychol. 2014;28(7):1146–61. PMID: 25249305.25249305
Rockhill CM, Tse YJ, Fesinmeyer MD, . Telepsychiatrists’ Medication Treatment Strategies in the Children’s Attention-Deficit/Hyperactivity Disorder Telemental Health Treatment Study. J Child Adolesc Psychopharmacol. 2015. PMID: 26258927.26258927
Rothenberger A, Becker A, Breuer D, . An observational study of once-daily modified-release methylphenidate in ADHD: Quality of life, satisfaction with treatment and adherence. European Child & Adolescent Psychiatry. 2011;20(Suppl 2):S257–S265.21901416
Sahin S, Yuce M, Alacam H, . Effect of methylphenidate treatment on appetite and levels of leptin, ghrelin, adiponectin, and brain-derived neurotrophic factor in children and adolescents with attention deficit and hyperactivity disorder. Int J Psychiatry Clin Pract. 2014;18(4):280–7. PMID: 24994482.24994482
Sangal RB and Sangal JM. Use of EEG Beta-1 Power and Theta/Beta Ratio Over Broca’s Area to confirm Diagnosis of Attention Deficit/Hyperactivity Disorder in Children. Clin EEG Neurosci. 2015;46(3):177–82. PMID: 24973230.24973230
Saylor K, Williams DW, Schuh KJ, . Effects of atomoxetine on self-reported high-risk behaviors and health-related quality of life in adolescents with ADHD. Curr Med Res Opin. 2010;26(9):2087–95. PMID: 20642391.20642391
Schreiber JM, Lanham DC, Trescher WH, . Variations in EEG discharges predict ADHD severity within individual Smith-Lemli-Opitz patients. Neurology. 2014;83(2):151–9. PMID: 24920862.24920862
Scott NG, Ripperger-Suhler J, Rajab MH, . Factors associated with atomoxetine efficacy for treatment of attention-deficit/hyperactivity disorder in children and adolescents. J Child Adolesc Psychopharmacol. 2010;20(3):197–203. PMID: 20578932.20578932
Shaywitz BA, Williams DW, Fox BK, . Reading outcomes of children and adolescents with attention-deficit/hyperactivity disorder and dyslexia following atomoxetine treatment. J Child Adolesc Psychopharmacol. 2014;24(8):419–25. PMID: 25299355.25299355
Shemmassian SK and Lee SS. Predictive Utility of Four Methods of Incorporating Parent and Teacher Symptom Ratings of ADHD for Longitudinal Outcomes J Clin Child Adolesc Psychol. 2015:1–12. PMID: 25643854.25643854
Sibley MH, Pelham WE, Molina BS, . The role of early childhood ADHD and subsequent CD in the initiation and escalation of adolescent cigarette, alcohol, and marijuana use. J Abnorm Psychol. 2014;123(2):362–74. PMID: 24886010.24886010
Sibley MH, Smith BH, Evans SW, . Treatment response to an intensive summer treatment program for adolescents with ADHD. Journal of Attention Disorders. 2012;16(6):443–448.22344319
Song J, Kim SW, Hong HJ, . Association of SNAP-25, SLC6A2, and LPHN3 with OROS methylphenidate treatment response in attention-deficit/hyperactivity disorder. Clin Neuropharmacol. 2014;37(5):136–41. PMID: 25229170.25229170
Sprafkin J, Mattison RE, Gadow KD, . A brief DSM-IV-referenced teacher rating scale for monitoring behavioral improvement in ADHD and co-occurring symptoms. J Atten Disord. 2011;15(3):235–45. PMID: 20228218.20228218
Su Y, Li H, Chen Y, . Remission Rate and Functional Outcomes during a 6-Month Treatment with Osmotic-Release Oral-System Methylphenidate in Children with Attention-Deficit/Hyperactivity Disorder. Journal of Clinical Psychopharmacology. 2015;35(5):525–534.26267421
Sumner CR, Gathercole S, Greenbaum M, . Atomoxetine for the treatment of attention-deficit/hyperactivity disorder (ADHD) in children with ADHD and dyslexia. Child Adolesc Psychiatry Ment Health. 2009;3:40. PMID: 20003507.20003507
Sumner CR, Haynes VS, Teicher MH, . Does placebo response differ between objective and subjective measures in children with attention-deficit/hyperactivity disorder?. Postgrad Med. 2010;122(5):52–61. PMID: 20861588.20861588
Tamm L, Nakonezny PA and Hughes CW. An open trial of a metacognitive executive function training for young children with ADHD. J Atten Disord. 2014;18(6):551–9. PMID: 22647287.22647287
Tanidir IC, Tanidir C, Ozturk E, . Effects of atomoxetine on heart rhythm in children and adolescents. Pediatr Int. 2015. PMID: 26096186.26096186
Taşğın EC, Oner O, Yurtbasi P, . Effects of maternal symptom ratings and other clinical features on short-term treatment response to OROS methylphenidate in children and adolescents with adhd in a naturalistic clinical setting. Klinik Psikofarmakoloji Bulteni. 2016;26(2):126–133.27746700
Topczewski A. Attention deficit and hyperactivity disorder: a therapeutic option. Einstein (Sao Paulo). 2014;12(3):310–3. PMID: 25295451.25295451
Torres A, Whitney J, Rao S, . Tolerability of atomoxetine for treatment of pediatric attention-deficit/hyperactivity disorder in the context of epilepsy. Epilepsy Behav. 2011;20(1):95–102. PMID: 21146461.21146461
Treuer T, Feng Q, Desaiah D, . Predictors of pharmacological treatment outcomes with atomoxetine or methylphenidate in patients with attention-deficit/hyperactivity disorder from China, Egypt, Lebanon, Russian Federation, Taiwan, and United Arab Emirates. Int J Clin Pract. 2014;68(9):1152–60. PMID: 24703228.24703228
Tsai CS, Huang YS, Wu CL, . Long-term effects of stimulants on neurocognitive performance of Taiwanese children with attention-deficit/hyperactivity disorder. BMC Psychiatry. 2013;13:330. PMID: 24305033.24305033
Turgay A, Ginsberg L, Sarkis E, . Executive function deficits in children with attention-deficit/hyperactivity disorder and improvement with lisdexamfetamine dimesylate in an open-label study. J Child Adolesc Psychopharmacol. 2010;20(6):503–11. PMID: 21186969.21186969
Tzang RF, Wang YC, Yeh CB, . Naturalistic exploration of the effect of osmotic release oral system-methylphenidate on remission rate and functional improvement in Taiwanese children with attention-deficit-hyperactivity disorder. Psychiatry Clin Neurosci. 2012;66(1):53–63. PMID: 22250610.22250610
Uebel-von Sandersleben H, Rothenberger A, Albrecht B, . Ginkgo biloba extract EGb 761(R) in children with ADHD. Z Kinder Jugendpsychiatr Psychother. 2014;42(5):337–47. PMID: 25163996.25163996
Uebel-von Sandersleben H, Rothenberger A, Albrecht B, . Ginkgo biloba Extract EGb 761® in Children with ADHD: Preliminary Findings of an Open Multilevel Dose-Finding Study. Zeitschrift für Kinder- und Jugendpsychiatrie und Psychotherapie. 2014;42(5):337–347.25163996
Vakula IN, Vasyanina YS, Gorbunova ZK, . Efficacy of Strattera in children and adolescents with attention deficit hyperactivity disorder. Neuroscience and Behavioral Physiology. 2010;40(9):1034–1037.
Valdizan-Uson JR, Canovas-Martinez A, De Lucas-Taracena MT, . Response to methylphenidate by adult and pediatric patients with attention-deficit/hyperactivity disorder: the Spanish multicenter DIHANA study. Neuropsychiatr Dis Treat. 2013;9:211–8. PMID: 23430373.23430373
van der Oord S, Bögels SM and Peijnenburg D. The effectiveness of mindfulness training for children with ADHD and mindful parenting for their parents. Journal of Child and Family Studies. 2012;21(1):139–147.22347788
Vaughn AJ, Epstein JN, Rausch J, . Relation between outcomes on a continuous performance test and ADHD symptoms over time. J Abnorm Child Psychol. 2011;39(6):853–64. PMID: 21476025.21476025
Visser SN, Bitsko RH, Danielson ML, . Treatment of Attention Deficit/Hyperactivity Disorder among Children with Special Health Care Needs. J Pediatr. 2015;166(6):1423–30.e1–2. PMID: 25841538.25841538
Walitza S, Kampf K, Artamonov N, . No elevated genomic damage in children and adolescents with attention deficit/hyperactivity disorder after methylphenidate therapy. Toxicol Lett. 2009;184(1):38–43. PMID: 19015014.19015014
Wang LJ, Chen CK and Huang YS. Gender Differences in the Behavioral Symptoms and Neuropsychological Performance of Patients with Attention-Deficit/Hyperactivity Disorder Treated with Methylphenidate: A Two-Year Follow-up Study. J Child Adolesc Psychopharmacol. 2015;25(6):501–8. PMID: 26262904.26262904
Wang LJ, Chen CK and Huang YS. Neurocognitive performance and behavioral symptoms in patients with attention-deficit/hyperactivity disorder during twenty-four months of treatment with methylphenidate. J Child Adolesc Psychopharmacol. 2015;25(3):246–53. PMID: 25574708.25574708
Wang LJ, Huang YS, Chiang YL, . Clinical symptoms and performance on the Continuous Performance Test in children with attention deficit hyperactivity disorder between subtypes: a natural follow-up study for 6 months. BMC Psychiatry. 2011;11:65. PMID: 21504587.21504587
Wang LJ, Wu CC, Lee SY, . Salivary neurosteroid levels and behavioural profiles of children with attention-deficit/hyperactivity disorder during six months of methylphenidate treatment. J Child Adolesc Psychopharmacol. 2014;24(6):336–40. PMID: 24956271.24956271
Warshaw EM, Squires L, Li Y, . Methylphenidate transdermal system: a multisite, open-label study of dermal reactions in pediatric patients diagnosed with ADHD. Prim Care Companion J Clin Psychiatry. 2010;12(6). PMID: 21494336.21494336
Webster-Stratton C, Reid MJ and Beauchaine TP. One-year follow-up of combined parent and child intervention for young children with ADHD. J Clin Child Adolesc Psychol. 2013;42(2):251–61. PMID: 23020199.23020199
Wehmeier PM, Dittmann RW and Banaschewski T. Treatment compliance or medication adherence in children and adolescents on ADHD medication in clinical practice: results from the COMPLY observational study. Atten Defic Hyperact Disord. 2015;7(2):165–74. PMID: 25416667.25416667
Wehmeier PM, Dittmann RW, Schacht A, . Morning and evening behavior in children and adolescents treated with atomoxetine once daily for Attention-Deficit/Hyperactivity Disorder (ADHD): Findings from two 24-week, open-label studies. Child and Adolescent Psychiatry and Mental Health. 2009;3.
Wietecha LA, Williams DW, Herbert M, . Atomoxetine treatment in adolescents with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(6):719–30. PMID: 20035590.20035590
Wigal SB, Maltas S, Crinella F, . Reading performance as a function of treatment with lisdexamfetamine dimesylate in elementary school children diagnosed with ADHD. J Atten Disord. 2012;16(1):23–33. PMID: 20978273.20978273
Yilmaz A, Gokcen C, Fettahoglu EC, . The effect of methylphenidate on executive functions in children with Attention-Deficit Hyperactivity Disorder. Klinik Psikofarmakoloji Bulteni. 2013;23(2):162–170.
Zelnik N and Terkel-Dawer R. The clinical profile of children with ADHD that require OROS-methylphenidate combined with shorter-acting formulations. Atten Defic Hyperact Disord. 2015;7(4):313–8. PMID: 25838111.25838111

### Does Not Include Outcomes of Interest

Adisetiyo V, Jensen JH, Tabesh A, . Multimodal MR imaging of brain iron in attention deficit hyperactivity disorder: a noninvasive biomarker that responds to psychostimulant treatment?. Radiology. 2014;272(2):524–32. PMID: 24937545.24937545
Adriaanse M, van Domburgh L, Zwirs B, . School-based screening for psychiatric disorders in Moroccan-Dutch youth. Child and Adolescent Psychiatry and Mental Health. 2015;9(1).
Alba-Sanchez F, Yanez-Suarez O and Brust-Carmona H. Assisted diagnosis of attention-deficit hyperactivity disorder through EEG bandpower clustering with self-organizing maps. Conf Proc IEEE Eng Med Biol Soc. 2010:2447–50. PMID: 21095960.21095960
Amer DA, Rakhawy MY and El Kholy SH. Quantitative EEG in children with attention deficit hyperactivity disorder. Egyptian Journal of Neurology, Psychiatry and Neurosurgery. 2010;47(3):399–406.
Amiri S, Shafiee-Kandjani AR, Noorazar SG, . Knowledge and Attitude of Parents of Children With Attention Deficit Hyperactivity Disorder Towards the Illness. Iran J Psychiatry Behav Sci. 2016;10(2):e122. PMID: 27803715.27803715
Anjana Y, Khaliq F and Vaney N. Event-related potentials study in attention deficit hyperactivity disorder. Funct Neurol. 2010;25(2):87–92. PMID: 20923606.20923606
Bailey UL, Derefinko KJ, Milich R, . The effects of stimulant medication on free recall of story events among children with ADHD. Journal of Psychopathology and Behavioral Assessment. 2011;33(4):409–419.
Bakhtadze S, Beridze M, Geladze N, . Effect of EEG Biofeedback on Cognitive Flexibility in Children with Attention Deficit Hyperactivity Disorder With and Without Epilepsy. Appl Psychophysiol Biofeedback. 2015. PMID: 26346570.26346570
Barry RJ, Clarke AR, Hajos M, . Acute atomoxetine effects on the EEG of children with attention-deficit/hyperactivity disorder. Neuropharmacology. 2009;57(7–8):702–707.19698723
Becker A, Rothenberger A and Sohn A. Six years ahead: a longitudinal analysis regarding course and predictive value of the Strengths and Difficulties Questionnaire (SDQ) in children and adolescents. European Child and Adolescent Psychiatry. 2015;24(6):715–725.25450722
Bekker J, Bruck D and Sciberras E. Congruent validity of the Strengths and Difficulties Questionnaire to screen for comorbidities in children with ADHD. Journal of Attention Disorders. 2016;20(10):879–888. PMID: 2016-42395-007.23881559
Beyer Von Morgenstern S, Becker I and Sinzig J. Improvement of facial affect recognition in children and adolescents with attention-deficit/hyperactivity disorder under methylphenidate. Acta Neuropsychiatrica. 2013;26(4):202–208.
Bigorra A, Garolera M, Guijarro S, . Long-term far-transfer effects of working memory training in children with ADHD: a randomized controlled trial. Eur Child Adolesc Psychiatry. 2015. PMID: 26669692.26669692
Bigorra AG, M.; Guijarro, S.; Hervas, A.. Impact of working memory training on hot executive functions (decision-making and theory of mind) in children with ADHD: a randomized controlled trial. Neuropsychiatry (London). 2016;6(5):251–263.
Bilder RM, Loo SK, McGough JJ, . Cognitive Effects of Stimulant, Guanfacine, and Combined Treatment in Child and Adolescent Attention-Deficit/Hyperactivity Disorder. J Am Acad Child Adolesc Psychiatry. 2016;55(8):667–73. PMID: 27453080.27453080
Bink M, van Nieuwenhuizen C, Popma A, . Neurocognitive effects of neurofeedback in adolescents with ADHD: a randomized controlled trial. J Clin Psychiatry. 2014;75(5):535–42. PMID: 24922488.24922488
Cassuto H, Ben-Simon A and Berger I. Using environmental distractors in the diagnosis of ADHD. Frontiers in Human Neuroscience. 2013(NOV.
Chelonis JJ, Johnson TA, Ferguson SA, . Effect of methylphenidate on motivation in children with attention-deficit/hyperactivity disorder. Experimental and Clinical Psychopharmacology. 2011;19(2):145–153.21463072
Chuang LY, Tsai YJ, Chang YK, . Effects of acute aerobic exercise on response preparation in a Go/No Go Task in children with ADHD: An ERP study. Journal of Sport and Health Science. 2015;4(1):82–88.
Chutko LS, Surushkina SY, Nikishena IS, . Use of Adaptol in the treatment of attention deficit hyperactivity disorder in children. Neuroscience and Behavioral Physiology. 2010;40(9):1038–1041.
Co JP, Johnson SA, Poon EG, . Electronic health record decision support and quality of care for children with ADHD. Pediatrics. 2010;126(2):239–46. PMID: 20643719.20643719
Dalsgaard S, Mortensen PB, Frydenberg M, . Association between Attention-Deficit Hyperactivity Disorder in childhood and schizophrenia later in adulthood. Eur Psychiatry. 2014;29(4):259–63. PMID: 24016863.24016863
de Jong CG, Van De Voorde S, Roeyers H, . Differential effects of atomoxetine on executive functioning and lexical decision in attention-deficit/hyperactivity disorder and reading disorder. J Child Adolesc Psychopharmacol. 2009;19(6):699–707. PMID: 20035588.20035588
DeVito EE, Blackwell AD, Clark L, . Methylphenidate improves response inhibition but not reflection-impulsivity in children with attention deficit hyperactivity disorder (ADHD). Psychopharmacology (Berl). 2009;202(1–3):531–9. PMID: 18818905.18818905
Diamond G, Badir M, Sevilla P, . Comparison between neurological examination and computerized test of attention for suspected ADHD: Implications for assessment of a common childhood disability. International Journal on Disability and Human Development. 2013;12(3):289–295.
Diomšina B, Rasmussen PD and Danilevičiute V. Clinical experience of long-term treatment with aripiprazole (abilify) in children and adolescents at the child and adolescent psychiatric clinic 1 in Roskilde, Denmark. Acta Poloniae Pharmaceutica - Drug Research. 2015;72(3):597–606.
Fabiano GA, Pelham WE, Cunningham CE, . A waitlist-controlled trial of behavioral parent training for fathers of children with ADHD. J Clin Child Adolesc Psychol. 2012;41(3):337–45. PMID: 22397639.22397639
Fernandez de la Cruz L, Simonoff E, McGough JJ, . Treatment of children with attention-deficit/hyperactivity disorder (ADHD) and irritability: results from the multimodal treatment study of children with ADHD (MTA). J Am Acad Child Adolesc Psychiatry. 2015;54(1):62–70.e3. PMID: 25524791.25524791
Firouzkouhi Moghaddam M, Rakhshani T and Khosravi M. Effectiveness of methylphenidate supplemented by zinc, calcium, and magnesium for treatment of ADHD patients in the city of Zahedan. Shiraz E Medical Journal. 2016;17(9).
Flisiak-Antonijczuk H, Adamowska S, Chladziñska-Kiejna S, . Treatment of ADHD: Comparison of EEG-biofeedback and methylphenidate. Archives of Psychiatry and Psychotherapy. 2015;17(4):32–38.
Forehand R, Parent J, Sonuga-Barke E, . Which Type of Parent Training Works Best for Preschoolers with Comorbid ADHD and ODD? A Secondary Analysis of a Randomized Controlled Trial Comparing Generic and Specialized Programs. J Abnorm Child Psychol. 2016. PMID: 26909683.26909683
Fried R, Hirshfeld-Becker D, Petty C, . How Informative Is the CANTAB to Assess Executive Functioning in Children With ADHD? A Controlled Study. J Atten Disord. 2015;19(6):468–75. PMID: 22923781.22923781
Gelade K, Bink M, Janssen TW, . An RCT into the effects of neurofeedback on neurocognitive functioning compared to stimulant medication and physical activity in children with ADHD. Eur Child Adolesc Psychiatry. 2016. PMID: 27665293.27665293
Gevensleben H, Holl B, Albrecht B, . Distinct EEG effects related to neurofeedback training in children with ADHD: a randomized controlled trial. Int J Psychophysiol. 2009;74(2):149–57. PMID: 19712709.19712709
Ghanizadeh A and Haddad B. The effect of dietary education on ADHD, a randomized controlled clinical trial. Ann Gen Psychiatry. 2015;14:12. PMID: 25767556.25767556
Gonzalez MA, Campbell D and Rubin J. Effects of application to two different skin sites on the pharmacokinetics of transdermal methylphenidate in pediatric patients with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2009;19(3):227–32. PMID: 19519257.19519257
Görtz-Dorten A, Breuer D, Hautmann C, . What contributes to patient and parent satisfaction with medication in the treatment of children with ADHD? A report on the development of a new rating scale. European Child & Adolescent Psychiatry. 2011;20(Suppl 2):S297–S307. PMID: 2011-22383-007.21901412
Gow RV, Hibbeln JR and Parletta N. Current evidence and future directions for research with omega-3 fatty acids and attention deficit hyperactivity disorder. Curr Opin Clin Nutr Metab Care. 2015;18(2):133–8. PMID: 25581035.25581035
Gray SA, Chaban P, Martinussen R, . Effects of a computerized working memory training program on working memory, attention, and academics in adolescents with severe LD and comorbid ADHD: a randomized controlled trial. J Child Psychol Psychiatry. 2012;53(12):1277–84. PMID: 22978357.22978357
Greenfield B, Hechtman L, Stehli A, . Sexual maturation among youth with ADHD and the impact of stimulant medication. Eur Child Adolesc Psychiatry. 2014;23(9):835–9. PMID: 24488239.24488239
Groen Y, Mulder LJ, Wijers AA, . Methylphenidate improves diminished error and feedback sensitivity in ADHD: An evoked heart rate analysis. Biol Psychol. 2009;82(1):45–53. PMID: 19464338.19464338
Guney E, Cetin FH, Alisik M, . Attention Deficit Hyperactivity Disorder and oxidative stress: A short term follow up study. Psychiatry Research. 2015;229(1–2):310–317.26188640
Haack LM, Villodas M, McBurnett K, . Parenting as a Mechanism of Change in Psychosocial Treatment for Youth with ADHD, Predominantly Inattentive Presentation. J Abnorm Child Psychol. 2016. PMID: 27628742.27628742
Halldorsdottir T, Ollendick TH, Ginsburg G, . Treatment Outcomes in Anxious Youth with and without Comorbid ADHD in the CAMS. J Clin Child Adolesc Psychol. 2015;44(6):985–91. PMID: 25310142.25310142
Hareendran A, Setyawan J, Pokrzywinski R, . Evaluating functional outcomes in adolescents with attention-deficit/hyperactivity disorder: Development and initial testing of a self-report instrument. Health and Quality of Life Outcomes. 2015;13(1).
Hidas A, Birman N, Noy AF, . Salivary bacteria and oral health status in medicated and non-medicated children and adolescents with attention deficit hyperactivity disorder (ADHD). Clin Oral Investig. 2013;17(8):1863–7. PMID: 23135427.23135427
Holmes J, Gathercole SE, Place M, . Working memory deficits can be overcome: Impacts of training and medication on working memory in children with ADHD. Applied Cognitive Psychology. 2010;24(6):827–836.
Holtmann M, Pniewski B, Wachtlin D, . Neurofeedback in children with attention-deficit/hyperactivity disorder (ADHD)--a controlled multicenter study of a non-pharmacological treatment approach. BMC Pediatr. 2014;14:202. PMID: 25123917.25123917
Huang YS, Wang LJ and Chen CK. Long-term neurocognitive effects of methylphenidate in patients with attention deficit hyperactivity disorder, even at drug-free status. BMC Psychiatry. 2012;12:194. PMID: 23140464.23140464
Hwang-Gu SL and Gau SSF. Interval timing deficits assessed by time reproduction dual tasks as cognitive endophenotypes for attention-deficit/hyperactivity disorder. PLoS ONE. 2015;10(5).
Jacobi-Polishook T, Shorer Z and Melzer I. The effect of methylphenidate on postural stability under single and dual task conditions in children with attention deficit hyperactivity disorder - a double blind randomized control trial. J Neurol Sci. 2009;280(1–2):15–21. PMID: 19217632.19217632
Jans T, Graf E, Jacob C, . A randomized controlled multicentre trial on the treatment for ADHD in mothers and children: enrolment and basic characteristics of the study sample. Atten Defic Hyperact Disord. 2013;5(1):29–40. PMID: 23070786.23070786
Janssen TW, Bink M, Gelade K, . A randomized controlled trial into the effects of neurofeedback, methylphenidate, and physical activity on EEG power spectra in children with ADHD. J Child Psychol Psychiatry. 2016;57(5):633–44. PMID: 26748531.26748531
Janssen TW, Bink M, Gelade K, . A Randomized Controlled Trial Investigating the Effects of Neurofeedback, Methylphenidate, and Physical Activity on Event-Related Potentials in Children with Attention-Deficit/Hyperactivity Disorder. J Child Adolesc Psychopharmacol. 2016;26(4):344–53. PMID: 26771913.26771913
Johnstone SJ, Roodenrys S, Blackman R, . Neurocognitive training for children with and without AD/HD. Atten Defic Hyperact Disord. 2012;4(1):11–23. PMID: 22179720.22179720
Jurbergs N, Palcic JL and Kelley ML. Daily Behavior Report Cards with and without Home-Based Consequences: Improving Classroom Behavior in Low Income, African American Children with ADHD. Child & Family Behavior Therapy. 2010;32(3):177–195.
Kang KD, Yun SW, Chung U, . Effects of methylphenidate on body index and physical fitness in Korean children with attention deficit hyperactivity disorder. Hum Psychopharmacol. 2016;31(2):76–82. PMID: 26756111.26756111
Kielbasa W, Quinlan T, Jin L, . Pharmacokinetics and pharmacodynamics of edivoxetine (LY2216684), a norepinephrine reuptake inhibitor, in pediatric patients with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. 2012;22(4):269–76. PMID: 22849510.22849510
Kwon HJ, Lim MH, Ha M, . Transferrin in Korean children with attention deficit hyperactivity disorder. Psychiatry Investigation. 2011;8(4):366–371.22216048
Lakes KD, Swanson JM and Riggs M. The reliability and validity of the English and Spanish Strengths and Weaknesses of ADHD and Normal behavior rating scales in a preschool sample: continuum measures of hyperactivity and inattention. J Atten Disord. 2012;16(6):510–6. PMID: 21807955.21807955
Langberg JM, Vaughn AJ, Brinkman WB, . Clinical utility of the Vanderbilt ADHD Rating Scale for ruling out comorbid learning disorders. Pediatrics. 2010;126(5):e1033–8. PMID: 20937653.20937653
Li S, Yu B, Lin Z, . Randomized-controlled study of treating attention deficit hyperactivity disorder of preschool children with combined electro-acupuncture and behavior therapy. Complement Ther Med. 2010;18(5):175–83. PMID: 21056840.21056840
Lin HY, Lee P, Chang WD, . Effects of weighted vests on attention, impulse control, and on-task behavior in children with attention deficit hyperactivity disorder. Am J Occup Ther. 2014;68(2):149–58. PMID: 24581401.24581401
Loo SK, Bilder RM, Cho AL, . Effects of d-Methylphenidate, Guanfacine, and Their Combination on Electroencephalogram Resting State Spectral Power in Attention-Deficit/Hyperactivity Disorder. J Am Acad Child Adolesc Psychiatry. 2016;55(8):674–682.e1. PMID: 27453081.27453081
Maoz H, Tsviban L, Gvirts HZ, . Stimulants improve theory of mind in children with attention deficit/hyperactivity disorder. Journal of Psychopharmacology. 2014;28(3):212–219. PMID: 2014-10977-003.23761389
McCarty CA, Stoep AV, Violette H, . Interventions developed for psychiatric and behavioral treatment in the children’s ADHD Telemental Health Treatment Study. Journal of Child and Family Studies. 2015;24(6):1735–1743. PMID: 2014-20776-001.
Meftagh SD, Najimi A, Mohammadi N, . The most effective intervention for attention deficit-hyperactivity disorder: using continuous performance test. Psychiatr Danub. 2014;26(2):165–71. PMID: 24909254.24909254
Merrill BM, Morrow AS, Altszuler AR, . Improving Homework Performance Among Children With ADHD: A Randomized Clinical Trial. J Consult Clin Psychol. 2016. PMID: 27618639.27618639
O’Connor BC, Fabiano GA, Waschbusch DA, . Effects of a summer treatment program on functional sports outcomes in young children with ADHD. J Abnorm Child Psychol. 2014;42(6):1005–17. PMID: 24362766.24362766
Ota T, Iida J, Nakanishi Y, . Increased prefrontal hemodynamic change after atomoxetine administration in pediatric attention-deficit/hyperactivity disorder as measured by near-infrared spectroscopy. Psychiatry and Clinical Neurosciences. 2015;69(3):161–170.25359429
Perera H, Jeewandara KC, Seneviratne S, . Combined ω_3_ and ω6 supplementation in children with attention-deficit hyperactivity disorder (ADHD) refractory to methylphenidate treatment: A double-blind, placebo-controlled study. Journal of Child Neurology. 2012;27(6):747–753.22596014
Prins PJ, Dovis S, Ponsioen A, . Does computerized working memory training with game elements enhance motivation and training efficacy in children with ADHD?. Cyberpsychol Behav Soc Netw. 2011;14(3):115–22. PMID: 20649448.20649448
Pritchard AE, Koriakin T, Jacobson LA, . Incremental validity of neuropsychological assessment in the identification and treatment of youth with ADHD. Clin Neuropsychol. 2014;28(1):26–48. PMID: 24345262.24345262
Rajwan E, Chacko A, Wymbs BT, . Evaluating clinically significant change in mother and child functioning: comparison of traditional and enhanced behavioral parent training. J Abnorm Child Psychol. 2014;42(8):1407–12. PMID: 24740438.24740438
Ramtvedt BE, Sandvik L and Sundet K. Correspondence between children’s and adults’ ratings of stimulant-induced changes in ADHD behaviours in a crossover trial with medication-naive children. European Journal of Developmental Psychology. 2014;11(6):687–700. PMID: 2014-33449-005.
Rivera-Flores GW. Self-instructional cognitive training to reduce impulsive cognitive style in children with attention deficit with hyperactivity disorder. Electronic Journal of Research in Educational Psychology. 2015;13(1):27–46.
Rooney M, Hinshaw S, McBurnett K, . Parent Adherence in Two Behavioral Treatment Strategies for the Predominantly Inattentive Presentation of ADHD J Clin Child Adolesc Psychol. 2016:1–9. PMID: 27808556.27808556
Rubia K, Alegria AA, Cubillo AI, . Effects of stimulants on brain function in attention-deficit/hyperactivity disorder: a systematic review and meta-analysis. Biol Psychiatry. 2014;76(8):616–28. PMID: 24314347.24314347
Rundberg-Rivera EV, Townsend LD, Schneider J, . Participant satisfaction in a study of stimulant, parent training, and risperidone in children with severe physical aggression. J Child Adolesc Psychopharmacol. 2015;25(3):225–33. PMID: 25885012.25885012
Saadat F, Kosha M, Amiry A, . Brain-derived neurotrophic factor as a biomarker in children with attention deficit-hyperactivity disorder. Journal of Krishna Institute of Medical Sciences University. 2015;4(4):10–17.
Sadatnezhad K, Boostani R and Ghanizadeh A. Proposing an adaptive mutation to improve XCSF performance to classify ADHD and BMD patients. J Neural Eng. 2010;7(6):066006. PMID: 21048285.21048285
Salehi B, Mohammadbeigi A, Sheykholeslam H, . Omega-3 and Zinc supplementation as complementary therapies in children with attention-deficit/hyperactivity disorder. J Res Pharm Pract. 2016;5(1):22–6. PMID: 26985432.26985432
Schacht A, Escobar R, Wagner T, . Psychometric properties of the quality of life scale Child Health and Illness Profile-Child Edition in a combined analysis of five atomoxetine trials. Atten Defic Hyperact Disord. 2011;3(4):335–49. PMID: 21986814.21986814
Schweren LJ, Hartman CA, Zwiers MP, . Combined stimulant and antipsychotic treatment in adolescents with attention-deficit/hyperactivity disorder: a cross-sectional observational structural MRI study. Eur Child Adolesc Psychiatry. 2015;24(8):959–68. PMID: 25395383.25395383
Setyawan J, Hodgkins P, Guerin A, . Comparing treatment adherence of lisdexamfetamine and other medications for the treatment of attention deficit/hyperactivity disorder: a retrospective analysis. J Med Econ. 2013;16(7):962–75. PMID: 23621503.23621503
Setyawan J, Hodgkins P, Guerin A, . Comparison of therapy augmentation and deviation rates from the recommended once-daily dosing regimen between LDX and commonly prescribed long-acting stimulants for the treatment of ADHD in youth and adults. J Med Econ. 2013;16(10):1203–15. PMID: 23937642.23937642
Shaw P, Sharp WS, Morrison M, . Psychostimulant treatment and the developing cortex in attention deficit hyperactivity disorder. Am J Psychiatry. 2009;166(1):58–63. PMID: 18794206.18794206
Shiels K, Hawk LW, Jr., Reynolds B, . Effects of methylphenidate on discounting of delayed rewards in attention deficit/hyperactivity disorder. Exp Clin Psychopharmacol. 2009;17(5):291–301. PMID: 19803628.19803628
Sibley MH, Altszuler AR, Ross JM, . A Parent-Teen Collaborative Treatment Model for Academically Impaired High School Students With ADHD. Cognitive and Behavioral Practice. 2014;21(1):32–42.
Sikirica V, Pliszka SR, Betts KA, . Impact of atypical antipsychotic use among adolescents with attention-deficit/hyperactivity disorder. Am J Manag Care. 2014;20(9):711–21. PMID: 25365746.25365746
Silva D, Colvin L, Glauert R, . Contact with the juvenile justice system in children treated with stimulant medication for attention deficit hyperactivity disorder: a population study. Lancet Psychiatry. 2014;1(4):278–85. PMID: 26360861.26360861
Silva D, Houghton S, Hagemann E, . Child Attention Deficit Hyperactive Disorder co morbidities on family stress: Effect of medication. Community Mental Health Journal. 2015;51(3):347–353.25154408
Spencer SV, Hawk LW, Jr., Richards JB, . Stimulant treatment reduces lapses in attention among children with ADHD: the effects of methylphenidate on intra-individual response time distributions. J Abnorm Child Psychol. 2009;37(6):805–16. PMID: 19291387.19291387
Springer C and Reddy LA. Measuring parental treatment adherence in a multimodal treatment program for children with ADHD: A preliminary investigation. Child & Family Behavior Therapy. 2010;32(4):272–290.
Steeger CM, Gondoli DM, Gibson BS, . Combined cognitive and parent training interventions for adolescents with ADHD and their mothers: A randomized controlled trial. Child Neuropsychol. 2015:1–26. PMID: 25731907.25731907
Stray LL, Ellertsen B and Stray T. Motor function and methylphenidate effect in children with attention deficit hyperactivity disorder. Acta Paediatr. 2010;99(8):1199–204. PMID: 20298494.20298494
Sundquist J, Ohlsson H, Sundquist K, . Attention-deficit/hyperactivity disorder and risk for drug use disorder: A population-based follow-up and co-relative study. Psychological Medicine. 2015;45(5):977–983.25119068
Tamm L and Nakonezny PA. Metacognitive executive function training for young children with ADHD: a proof-of-concept study. ADHD Attention Deficit and Hyperactivity Disorders. 2015;7(3):183–190.25559877
Tamm L, Epstein JN, Peugh JL, . Preliminary data suggesting the efficacy of attention training for school-aged children with ADHD. Dev Cogn Neurosci. 2013;4:16–28. PMID: 23219490.23219490
Tarakçıoğlu MC, Çakın Memik N, Olgun NN, . Turkish validity and reliability study of the Weiss Functional Impairment Rating Scale-Parent Report. ADHD Attention Deficit and Hyperactivity Disorders. 2015;7(2):129–139.25428590
Tucker JD, Suter W, Petibone DM, . Cytogenetic assessment of methylphenidate treatment in pediatric patients treated for attention deficit hyperactivity disorder. Mutat Res. 2009;677(1–2):53–8. PMID: 19465145.19465145
van der Kolk A, Bouwmans CA, Schawo SJ, . Association between societal costs and treatment response in children and adolescents with ADHD and their parents. A cross-sectional study in the Netherlands. Springerplus. 2015;4:224. PMID: 26155437.26155437
Wehrmann T and Müller JM. An objective measure of hyperactivity aspects with compressed webcam video. Child and Adolescent Psychiatry and Mental Health. 2015;9(1).
Wilkes-Gillan S, Bundy A, Cordier R, . A Randomised Controlled Trial of a Play-Based Intervention to Improve the Social Play Skills of Children with Attention Deficit Hyperactivity Disorder (ADHD). PLoS One. 2016;11(8):e0160558. PMID: 27529693.27529693
Wu Q, Zhou T, Ma L, . Protective effects of dietary supplementation with natural omega-3 polyunsaturated fatty acids on the visual acuity of school-age children with lower IQ or attention-deficit hyperactivity disorder. Nutrition. 2015;31(7–8):935–40. PMID: 26015389.26015389
Yalcin O, Iseri E, Bukan N, . Effects of long acting methylphenidate on ghrelin levels in male children with attention deficit hyperactivity disorder: An open label trial. Klinik Psikofarmakoloji Bulteni. 2014;24(2):146–157.
Zarrabi M, Shahrivar Z, Tehrani Doost M, . Concurrent validity of the behavior rating inventory of executive function in children with attention deficit hyperactivity disorder. Iranian Journal of Psychiatry and Behavioral Sciences. 2015;9(1).
Zhang L, Jin X and Zhang Y. Effect of methylphenidate on intelligence quotient scores in Chinese children with attention-deficit/hyperactivity disorder. J Clin Psychopharmacol. 2011;31(1):51–5. PMID: 21192143.21192143
Zheng Y, Liang JM, Gao HY, . An Open-label, Self-control, Prospective Study on Cognitive Function, Academic Performance, and Tolerability of Osmotic-release Oral System Methylphenidate in Children with Attention-deficit Hyperactivity Disorder. Chin Med J (Engl). 2015;128(22):2988–97. PMID: 26608976.26608976

### Timing or Setting Not Applicable

Huss M, Sikirica V, Hervas A, . Guanfacine extended release for children and adolescents with attention-deficit/hyperactivity disorder: efficacy following prior methylphenidate treatment. Neuropsychiatr Dis Treat. 2016;112:1085–101. PMID: 27226715.27226715
Matsudaira T, Gow RV, Kelly J, . Biochemical and Psychological Effects of Omega-3/6 Supplements in Male Adolescents with Attention-Deficit/Hyperactivity Disorder: A Randomized, Placebo-Controlled, Clinical Trial. J Child Adolesc Psychopharmacol. 2015;25(10):775–82. PMID: 26682998.26682998
McCracken JT, McGough JJ, Loo SK, . Combined Stimulant and Guanfacine Administration in Attention-Deficit/Hyperactivity Disorder: A Controlled, Comparative Study. Journal of the American Academy of Child and Adolescent Psychiatry. 2016.
Williams LM, Hermens DF, Thein T, . Using brain-based cognitive measures to support clinical decisions in ADHD. Pediatr Neurol. 2010;42(2):118–26. PMID: 20117748.20117748