# Appendix B Data Abstraction Elements

## Study Characteristics

- Study Identifiers
  ○ Study Name or Acronym
  ○ NCT number or other trial registry identifier
  ○ Last name of first author
- Additional Articles Used in This Abstraction
- Study Sites
  ○ Single center, Multicenter, Unclear/Not reported
  ○ Number of sites
- Geographic Location (Select all that apply)
  ○ US, Canada, UK/Europe, Latin America, Middle East (including Israel), Asia, Africa, Australia/NZ, Unclear/Not reported
- Study Design
  ○ RCT
  ○ Observational
- Funding Source (Select all that apply)
  ○ Government, Industry, Non-government/non-industry, Unclear/Not reported
- Setting (Select all that apply)
  ○ Primary Care; Specialty Care; Community Resource; School; Other; Unclear/Not reported
- Study Enrollment/Study Completion
  ○ N enrolled/included
  ○ N completed
- Key Question Applicability (Select all that apply)
  ○ KQ1, KQ2, KQ3
- Comments

Baseline Characteristics – Record the following elements for Total Population, Total ADHD Population, Arm 1, Arm 2, Arm 3, and Arm 4 (as applicable)

○ Number of Patients (N and %)
○ Gender (N and %)
  ■ Male
  ■ Female
○ Age in years
  ■ Mean
  ■ Median
  ■ Standard Deviation
  ■ Min. age
  ■ Max. age
  ■ 25% IQR
  ■ 75% IQR
  ■ Categorical
  ■ Other, specify
○ Race/Ethnicity (N and %)
  ■ Hispanic or Latino
  ■ Black/African American
  ■ American Indian or Alaska Native
  ■ Asian
  ■ Native Hawaiian or Pacific Islander
  ■ White
  ■ Multiracial
  ■ Other (specify)
○ ADHD Subtype (N and %)
  ■ Inattentive
  ■ Hyperactive
  ■ Combined

- Were there significant differences noted between groups in any baseline characteristic? (Yes/No)
  ○ If yes, please explain the differences
- Comments

## Intervention Characteristics

- What intervention comparison is being tested in this study? Mark all that apply.
  ○ Pharmacological vs. pharmacological,
  ○ Pharmacological vs. non-pharmacological
  ○ Pharmacological vs. placebo/usual care
    ■ Placebo, Pharmacological Usual Care, Non-pharmacological Usual Care
  ○ Non-pharmacological vs. non-pharmacological
  ○ Non-pharmacological vs. placebo/usual care
    ■ Placebo, Pharmacological Usual Care, Non-pharmacological Usual Care
- Intervention Descriptors
  ○ Describe the intervention received by each patient group (For each Arm).
- Indicate components of the intervention (For each Arm)
  ○ Pharmacological
  ○ Nonpharmacological
  ○ Placebo or usual/standard care
- Indicate all intervention characteristics that are varied in this study
  ○ Pharmacological Details
    ■ Psychostimulants
      - Methylphenidate, Dexmethylphenidate, Dextroamphetamine, Lisdexamphetamine, Mixed amphetamine salts, Amphetamine
    ■ Tricyclic antidepressants
      - Desipramine, Nortriptyline
    ■ Selective norepinephrine reuptake inhibitors
      - Atomoxetine
    ■ Alpha-2 agonists
      - Clonidine, Guanfacine extended release
    ■ Dopamine reuptake inhibitors
      - Modafinil
      - Armodafinil
    ■ Norepinephrine-dopamine reuptake inhibitors
      - Bupropion
    ■ Serotonin-norepinephrine reuptake inhibitors
      - Duloxetine
    ■ Serotonin-norepinephrine-dopamine reuptake inhibitors
      - Venlafaxine
    ■ Monoamine oxidase type B inhibitors
      - Selegiline
    ■ N-methyl-D-aspartate receptor antagonists
      - Amantadine, Memantine
  ○ Nonpharmacological Details
    ■ Psychosocial interventions
    ■ Behavioral interventions
    ■ Cognitive behavioral therapy
    ■ Play therapy
    ■ Mindfulness-based therapies
    ■ School interventions
    ■ Cognitive training therapies
    ■ Biofeedback or neurofeedback
    ■ Parent behavior training
    ■ Dietary supplements
    ■ Homeopathy
    ■ Acupuncture
    ■ Elimination diets
    ■ Vision training
    ■ Exercise
    ■ Chiropractic treatment
  ○ Placebo/Control details
    ■ Placebo
    ■ Usual care control/optimal medical therapy
    ■ Other (specify)
  ○ Indicate the intervention target
    ■ ADHD patients
    ■ Parents
    ■ Teachers
    ■ Other (Specify)
  ○ Indicate the Intervention Setting
    ■ Primary Care
    ■ Specialty Care
    ■ Home
    ■ School
    ■ Other (specify)
- Duration of Follow-up reported for Total overall study f/u, Arm 1 f/u, Arm 2 f/u, Arm 3 f/u, Arm 4 f/u (Reported or Not reported)
  ■ Mean follow-up in months or years (include units)
  ■ Mean Variability
    - SD, SE, IQR, NR
  ■ Median Follow-up in months or years (include units)
  ■ Median variability
    - SD, SE, IQR, NR
- Comments

## KQ 1 Diagnostic Tools

- Gold Standard
  ○ Is confirmation of diagnosis by a specialist including psychologist or psychiatrist or other care provider using a well-validated and reliable process of confirming the diagnosis of ADHD according to the DSM-IV or DSM-V the gold standard?
    ■ Yes (Describe the gold standard)
    ■ No (Article may be eligible for exclusion. Please check with the team)
  ○ Who performed the diagnosis?
    ■ Specialist, other care, provider, researcher, unclear/NR, other (specify)
- Select the outcome(s) reported on this form:
  ○ Diagnostic Accuracy, Misdiagnosis/risk of missed condition, labeling/stigma
- Select the Age Group
  ○ Under 7 with any diagnostic tool, 7–17 with a novel diagnostic tool, labeling/stigma
- Subgroup Analyses
  ○ Is this outcome form for a subgroup of interest? (Y or N)
    ■ If Y, indicate the factor being considered
      - Age
      - Sex
      - ADHD presentation
      - Comorbidity (e.g. anxiety, depression)
      - Risk factors
      - Race/ethnicity
      - Socioeconomic status
      - Insurance status
      - Geographic location
      - Clinical setting
      - Any additional description/clarification of subgroup reported on this form
- Diagnostic Accuracy
  ○ Timing of the outcome data
  ○ Test results reported for Instrument 1, Instrument 2, Instrument 3 (Select instrument used)
    ■ True positive (# patients)
    ■ True negative (# patients)
    ■ False positive (# patients)
    ■ False negative (# patients)
    ■ Sensitivity
      - %, Std dev, Upper confidence interval bound, lower confidence interval bound
    ■ Specificity
      - %, Std dev, Upper confidence interval bound, lower confidence interval bound
    ■ Positive predictive value
      - %, Std dev, Upper confidence interval bound, lower confidence interval bound
    ■ Negative predictive value
      - %, Std dev, Upper confidence interval bound, lower confidence interval bound
    ■ Positive likelihood ratio
    ■ Negative likelihood ratio
  ○ Reliability
    ■ Test-retest
    ■ Kappa statistics
    ■ Inter-rater
    ■ Intra-rater
    ■ Intraclass correlation
    ■ Diagnostic concordance of primary care provider with specialist
    ■ Internal consistency
- Misdiagnosis/Risk of Missed Condition Measure
  ○ Timing of the outcome reported
  ○ Describe outcome
- Labeling/Stigma
  ○ Timing of the outcome data reported
  ○ Describe outcome
- Comments

## KQ 2 Outcomes

- Specific RefID
- Where was this data in the article found? (pg #, table #, etc)
- Select the outcome reported on this form:
  ○ Academic performance
  ○ Acceptability of treatment
  ○ Aggression
  ○ Behavior changes
  ○ Cardiac arrhythmias
  ○ Changes in appetite
  ○ Changes in standardized symptom scores or progress toward patient-identified goals
  ○ Chemical leukoderma
  ○ Conduction abnormalities
  ○ Depression or anxiety
  ○ Diversion of pharmacotherapy
  ○ Divorce/relationship status
  ○ Elevated blood pressure
  ○ Functional impairment
  ○ Gastrointestinal symptoms
  ○ Growth suppression
  ○ Hallucination
  ○ Incarceration or other interactions with the legal system
  ○ Increased heart rate
  ○ Loss of spontaneity
  ○ Mood disorders
  ○ Mortality
  ○ Motor vehicle collisions or other accidents
  ○ Motor vehicle violations
  ○ Obesity
  ○ Overtreatment
  ○ Parental stress
  ○ Personality change
  ○ Priapism
  ○ Quality of peer relationships
  ○ Risk of sudden cardiac death
  ○ Risk-taking behaviors
  ○ Self-injurious non-suicidal behavior
  ○ Sleep disturbance
  ○ Substance abuse
  ○ Suicide (attempted or completed)
  ○ Suicide ideation
  ○ Tics or other movement disorders
  ○ Time demands/opportunity cost
  ○ Tobacco use
  ○ Weight decrease
  ○ Workforce participation
- Any additional description/clarification of the outcome reported on this form
- Is this outcome form for a subgroup of interest? (Yes/No)
  ○ What subpopulation is this outcome reported for on this form?
    ■ Age
    ■ Sex
    ■ ADHD presentation
    ■ Comorbidity
    ■ Risk factors
    ■ Race/ethnicity
    ■ Socioeconomic status
    ■ Insurance status
    ■ Geographic location
    ■ Clinical setting
  ○ Any additional description/clarification of subgroup reported on this form
- Total N Analyzed for this outcome
- Timepoint reported on this form
  ○ Short-term
  ○ Long-term
- Specify actual timing of the outcome (in months)
- For each arm:
  ○ N Analyzed (enter UNK if unknown)
  ○ Unadjusted Result
    ■ Number of patients with outcome
    ■ % of patients with outcome
    ■ Events/denominator
    ■ Odds ratio
    ■ Hazard ratio
    ■ Relative risk
    ■ Mean
    ■ Median
    ■ Mean within group change
    ■ Mean between group change
    ■ Other (specify)
  ○ Unadjusted Result Variability
    ■ 95% CI
    ■ IQR
    ■ Standard Error (SE)
    ■ Standard Deviation (SD)
    ■ Other % CI (specify)
    ■ Other (specify)
  ○ Unadjusted Result, p-value between groups
  ○ Unadjusted Result, indicate reference group (for comparison between groups)
  ○ Adjusted Result
    ■ Number of patients with outcome
    ■ % of patients with outcome
    ■ Events/denominator
    ■ Odds ratio
    ■ Hazard ratio
    ■ Relative risk
    ■ Mean
    ■ Median
    ■ Mean within group change
    ■ Mean between group change
    ■ Other (specify)
  ○ Adjusted Result Variability
    ■ 95% CI
    ■ IQR
    ■ Standard Error (SE)
    ■ Standard Deviation (SD)
    ■ Other % CI (specify)
    ■ Other (specify)
  ○ Adjusted Result, p-value between groups
  ○ Adjusted Result, indicate reference group (for comparison between groups)
  ○ If adjusted data is recorded, indicate the adjustments applied
- Comments

## Quality

- Study Type (select one): RCT, Observational
- If RCT, select Yes/No/Unclear for each of the following questions:
  ○ Sequence Generation
    ■ Was the allocation sequence generated adequately (e.g., random number table, computer-generated randomization)?
  ○ Allocation concealment
    ■ Was the allocation of treatment adequately concealed (e.g., pharmacy-controlled randomization or use of sequentially numbered sealed envelopes)?
  ○ Blinding of participants, personnel and outcome assessors
    ■ Was knowledge of the allocated intervention adequately prevented during the study?
  ○ Incomplete outcome data
    ■ Were incomplete outcome data adequately addressed?
  ○ Selective outcome reporting
    ■ Are reports of the study free of suggestion of selective outcome reporting?
  ○ Other sources of bias
    ■ Was the study apparently free of other problems that could put it at a high risk of bias?
  ○ Comments
- If Observational, Study design (select one)
  ■ Case-control, Cohort
- If Case-Control:
  ○ Selection
    ■ Is the case definition adequate?
      - Yes, with independent validation
      - Yes, eg record linkage or based on self reports?
      - No description
      - comments
    ■ Representativeness of the cases
      - Consecutive or obviously representative series of cases
      - Potential for selection biases or not stated
      - comments
    ■ Selection of controls
      - Community controls
      - Hospital controls
      - No description
      - Comments
    ■ Definition of controls
      - No history of disease (endpoint)
      - No description of source
      - Comments
  ○ Comparability
    ■ Comparability of cases and controls on the basis of the design or analysis
      - Study controls for severity of ADHD
      - Study controls for any additional factor
      - Comments
  ○ Exposure
    ■ Ascertainment of exposure
      - Secure record
      - Structured interview where blind to case/control status
      - Interview not blinded to case/control status
      - Written self report or medical record only
      - No description
      - comments
    ■ Same method of ascertainment for cases and controls (Y, N, comments)
    ■ Non-response rate
      - Same rate for both groups
      - Non respondent described
      - Rate different and no designation
      - Comments
- If Cohort:
  ○ Selection
    ■ Representativeness of the exposed cohort Yes, with independent validation
      - Truly representative of the average ADHD patient in the community
      - Somewhat representative of the average ADHD patient in the community
      - Selected group of users (eg nurses, volunteers)
      - No description of the derivation of the cohort
      - Comments
    ■ Selection of the non-exposed cohort
      - Drawn from the same community as the exposed cohort
      - Drawn from a different source
      - No description of the derivation of the non-exposed cohort
      - Comments
    ■ Ascertainment of exposure
      - Secure record (e.g., surgical records)
      - Structured interview
      - Written self-report
      - No description
      - Comments
    ■ Demonstration that outcome of interest was not present at start of study (Y, N, Comments)
  ○ Comparability
    ■ Comparability of cohorts on the basis of the design or analysis
      - Study controls for severity of ADHD
      - Study controls for any additional factor
      - Comments
  ○ Outcome
    ■ Assessment of Outcome
      - Independent blind assortment
      - Record linkage
      - Self report
      - No description
      - comments
    ■ Was follow-up long enough for outcome to occur (Y, N, comments)
    ■ Adequacy of follow up of cohorts
      - Complete follow up - all subjects accounted for
      - Subjects lost to follow up unlikely to introduce bias - small number lost − >80% follow up, or description provided of those lost
      - Follow up rate
      - No statement
      - Comments
- Overall Study Rating (Good/Fair/Poor)
  ○ Good (low risk of bias). These studies have the least bias, and the results are considered valid. These studies adhere to the commonly held concepts of high quality, including the following: a clear description of the population, setting, approaches, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytical methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
  ○ Fair. These studies are susceptible to some bias, but not enough to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
  ○ Poor (high risk of bias). These studies have significant flaws that may have invalidated the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.
  ○ If the study is rated as “Fair” or “Poor,” provide rationale.
- Outcome-specific quality rating
  ○ Do you think that any of the outcomes abstracted for this study should be assigned a quality rating DIFFERENT from the overall study rating? (No/Yes)
    ■ If you think any of the abstracted outcomes should have a quality rating different from the overall study, please provide the outcome(s), rating(s) and rationale(s).

Applicability – Use the PICOS format to identify specific issues, if any, that may limit the applicability of the study.

- Population (P)
  ○ Narrow eligibility criteria and exclusion of those with comorbidities
  ○ More complex patients than typical of the community
  ○ Run-in period with high exclusion rate for non-adherence or side effects
  ○ DSM-4/5 diagnosis unclear
- Intervention (I)
  ○ as recommended or commonly used in practice
  ○ Dosing not reflective of current practice
  ○ Co-intervention that are likely to modify the effectiveness of therapy
  ○ Highly selected intervention team or level of training/proficiency not widely available
  ○ Follow-up not reflective of current practice
  ○ Co-intervention that are likely to modify monitoring strategies
- Comparator (C)
  ○ Diagnostic tools used differently than as recommended or commonly used in practice
  ○ Comparator unclear
  ○ Inadequate comparison therapy or use of a substandard alternative therapy
- Outcomes (O)
  ○ Composite outcomes that mix outcomes of different significance
  ○ Short-term follow-up
  ○ Surrogate outcomes
- Setting (S)
  ○ Level of care different from that in the community
- Do you have other concerns regarding applicability of this study? (Y, N, describe concerns)
- Comment