# Appendix A Exact Search Strings

## PubMed^®^ Search Strategy (November 4, 2016)

### Key Question 1

Set # | Terms
#1 | “Attention Deficit Disorder with Hyperactivity”[Mesh] OR “attention deficit hyperactivity disorder”[tiab] OR “ADHD”[tiab] OR “attention deficit disorder”[tiab]
#2 | “Pediatrics”[Mesh] OR “Adolescent”[Mesh] OR “Infant”[Mesh] OR “Child”[Mesh] OR child[tiab] OR children[tiab] OR infant[tiab] OR infants[tiab] OR preschool[tiab] OR preschooler[tiab] OR pediatric[tiab] OR teenager[tiab] OR teenagers[tiab] OR teenaged[tiab] OR teen[tiab] OR teens[tiab] OR adolescent[tiab] OR adolescents[tiab] OR adolescence[tiab] OR youth[tiab]
#3 | “Attention Deficit and Disruptive Behavior Disorders/diagnosis”[Majr] OR mass screening[mesh] OR questionnaires[mesh] OR Interviews as Topic[Mesh] OR Psychometrics[Mesh] OR Psychiatric Status Rating Scales[Mesh] OR diagnosis[mesh:noexp] OR “Diagnostic Techniques and Procedures”[Mesh] OR “Diagnostic and Statistical Manual of Mental Disorders”[Mesh] OR “Referral and Consultation”[Mesh] OR questionnaire[tiab] OR questionnaires[tiab] OR screening[tiab] OR screen[tiab] OR scale[tiab] OR instrument[tiab] OR instruments[tiab] OR interview[tiab] OR interviews[tiab] OR DSM*[tiab] OR diagnosis[tiab] OR diagnostic[tiab] OR diagnosed[tiab] OR (Vanderbilt[tiab] AND scale[tiab]) OR conners[tiab] OR cprs[tiab] OR ctrs[tiab] OR cprs[tiab] OR crs[tiab] OR “snap-IV”[tiab] OR “snap-4”[tiab] OR “basc-2”[tiab] OR “behavioral assessment system for children”[tiab] OR dbdrs[tiab] OR “disruptive behavior disorder rating scale”[tiab] OR adhd-rs[tiab] OR “adhd rating scale”[tiab] OR ksads[tiab] OR k-sads[tiab] OR kiddie-sads[tiab] OR DISC[tiab] OR “dominance inducement submission and compliance”[tiab] OR “diagnostic interview schedule for children”[tiab] OR “diagnostic inventory for screening children”[tiab] OR “mini-kid”[tiab] OR “Mini Interational Neuropsychiatric interview”[tiab] OR “iva-2”[tiab] OR “iva-qs”[tiab] OR “iva-ae2”[tiab] OR tova[tiab] OR “test of variables of attention”[tiab] OR “neuropsychiatric eeg-based assessment aid”[tiab] OR neba[tiab]
#4 | “Sensitivity and Specificity”[Mesh] OR “Diagnostic Errors”[Mesh] OR sensitivity[tiab] OR specificity[tiab] OR accuracy[tiab] OR accurate[tiab] OR accurately[tiab] OR misdiagnos*[tiab] OR (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR “evaluation studies”[pt] OR “evaluation studies as topic”[MeSH] OR “evaluation study”[tiab] OR evaluation studies[tiab] OR “intervention studies”[MeSH] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “case-control studies”[MeSH] OR “case-control”[tiab] OR “cohort studies”[MeSH] OR cohort[tiab] OR “longitudinal studies”[MeSH] OR “longitudinal”[tiab] OR longitudinally[tiab] OR “prospective”[tiab] OR prospectively[tiab] OR “retrospective studies”[MeSH] OR “retrospective”[tiab] OR “Cross-Sectional Studies”[Mesh] OR cross-sectional[tiab] OR “comparative study”[pt] OR “comparative study”[tiab] OR systematic[sb] OR “meta-analysis”[pt] OR “meta-analysis as topic”[MeSH] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab]) NOT (Editorial[ptyp] OR Letter[pt] OR Case Reports[pt] OR Comment[pt]) NOT (animals[mh] NOT humans[mh]) AND English[la]
#5 | #1 AND #2 AND #3 AND #4
| Publication date from 2009/01/01

### Key Question 2

Set # | Terms
#1 | “Attention Deficit Disorder with Hyperactivity”[Mesh] OR “attention deficit hyperactivity disorder”[tiab] OR “ADHD”[tiab] OR “attention deficit disorder”[tiab]
#2 | “Pediatrics”[Mesh] OR “Adolescent”[Mesh] OR “Infant”[Mesh] OR “Child”[Mesh] OR child[tiab] OR children[tiab] OR infant[tiab] OR infants[tiab] OR preschool[tiab] OR preschooler[tiab] OR pediatric[tiab] OR teenager[tiab] OR teenagers[tiab] OR teenaged[tiab] OR teen[tiab] OR teens[tiab] OR adolescent[tiab] OR adolescents[tiab] OR adolescence[tiab] OR youth[tiab]
#3 | #1 AND #2
#4 | “Attention Deficit Disorder with Hyperactivity/drug therapy”[Majr] OR “Central Nervous System Stimulants”[MeSH] OR “Methylphenidate”[MeSH] OR “Dexmethylphenidate”[MeSH] OR “Dextroamphetamine”[MeSH] OR “Adderall”[Supplementary Concept] OR “lisdexamfetamine dimesylate”[Supplementary Concept] OR “Amphetamine”[MeSH] OR “Guanfacine”[MeSH] OR “Sympatholytics”[MeSH] OR “Clonidine”[MeSH] OR “Adrenergic Uptake Inhibitors”[MeSH] OR “Adrenergic Uptake Inhibitors”[Pharmacological Action] OR “Receptors, Adrenergic, alpha-2”[MeSH] OR “Adrenergic alpha-Agonists”[Mesh] OR “Adrenergic alpha-2 Receptor Agonists”[Mesh] OR “atomoxetine”[Supplementary Concept] OR “Antidepressive Agents, Tricyclic”[MeSH] OR “Desipramine”[MeSH] OR “Dopamine Uptake Inhibitors”[MeSH] OR “Sympathomimetics”[MeSH] OR “modafinil”[Supplementary Concept] OR “Serotonin Uptake Inhibitors”[MeSH] OR “Serotonin Uptake Inhibitors”[Pharmacological Action] OR “duloxetine” [Supplementary Concept] OR “Monoamine Oxidase Inhibitors”[MeSH] OR “Monoamine Oxidase”[MeSH] OR “Selegiline”[MeSH] OR “Bupropion”[MeSH] OR “armodafinil” [Supplementary Concept] OR “venlafaxine”[Supplementary Concept] OR “Receptors, N-Methyl-D-Aspartate”[MeSH] OR “Memantine”[MeSH] OR “Amantadine”[MeSH] OR “duloxetine”[Supplementary Concept] OR “Central Nervous System Stimulants” [Pharmacological Action] OR “Adrenergic alpha-2 Receptor Agonists” [Pharmacological Action] OR “Antidepressive Agents, Tricyclic” [Pharmacological Action] OR “Dopamine Uptake Inhibitors” [Pharmacological Action] OR “Monoamine Oxidase Inhibitors” [Pharmacological Action] OR “Central Nervous System Stimulants”[tiab] OR “psychostimulant”[tiab] OR “Methylphenidate”[tiab] OR “Methylphenidate Hydrochloride”[tiab] OR “Aptensio”[tiab] OR “Concerta”[tiab] OR “Ritalin”[tiab] OR “Ritalin LA”[tiab] OR “Medikinet”[tiab] OR “Equasym”[tiab] OR “Quillivant”[tiab] OR “Metadate”[tiab] OR “Daytrana”[tiab] OR “Dexmethylphenidate”[tiab] OR “Dexmethylphenidate Hydrochloride”[tiab] OR “Focalin”[tiab] OR “Dextroamphetamine”[tiab] OR “Dexedrine”[tiab] OR “Dextrostat”[tiab] OR “ProCentra”[tiab] OR “Zenzedi”[tiab] OR “mixed amphetamine salts”[tiab] OR “Adderall” [tiab] OR “lisdexamfetamine”[tiab] OR “lisdexamfetamine dimesylate”[tiab] OR “Vyvanse”[tiab] OR “Venvanse”[tiab] OR “Elvanse”[tiab] OR “Tyvense”[tiab] OR “Dyanavel”[tiab] OR “Evekeo”[tiab] OR “Guanfacine”[tiab] OR “Sympatholytics”[tiab] OR “Central alpha-2 Adrenergic Agonist”[tiab] OR “Clonidine”[tiab] OR “Intuniv”[tiab] OR “Estulic”[tiab] OR “Tenex”[tiab] OR “Catapres”[tiab] OR “Clophelin”[tiab] OR “Kapvay”[tiab] OR “Nexiclon”[tiab] OR “Duraclon”[tiab] OR “Norepinephrine Reuptake Inhibitors”[tiab] OR “Selective Norepinephrine Reuptake Inhibitors”[tiab] OR “Adrenergic Uptake Inhibitors”[tiab] OR “atomoxetine”[tiab] OR “Strattera”[tiab] OR “Tricyclic antidepressants”[tiab] OR “Desipramine”[tiab] OR “Norpramin”[tiab] OR “Nortriptyline”[tiab] OR “Pamelor”[tiab] OR “Dopamine Reuptake Inhibitors”[tiab] OR “modafinil”[tiab] OR “Provigil”[tiab] OR “Armodafinil”[tiab] OR “Norepinephrine-dopamine Reuptake Inhibitors”[tiab] OR “Bupropion”[tiab] OR “Wellbutrin”[tiab] OR “Forfivo”[tiab] OR “Cymbalta”[tiab] OR “venlafaxine”[tiab] OR “reboxetine”[tiab] OR “Monoamine Oxidase Type B inhibitors”[tiab] OR “Selegiline”[tiab] OR “Eldepryl”[tiab] OR “Zelapar”[tiab] OR “NMDA receptors”[tiab] OR “N-Methyl-D-aspartate receptor Antagonists”[tiab] OR “Amantadine”[tiab] OR “Memantine”[tiab] OR “Pertofrane”[tiab] OR “Nuvigil”[tiab] OR “Cymbalta”[tiab] OR “duloxetine”[tiab] OR “Effexor”[tiab] OR “Eldepryl”[tiab] OR “Emsam”[tiab] OR “Trevilor”[tiab] OR “Symmetrel”[tiab] OR “Namenda”[tiab] OR “Zelapar”[tiab]
#5 | “Attention Deficit Disorder with Hyperactivity/diet therapy”[Majr] OR “Attention Deficit Disorder with Hyperactivity/rehabilitation”[Majr] OR “Psychotherapy”[MeSH] OR “Behavior Therapy”[MeSH] OR “Parent-Child Relations”[MeSH] OR “Play Therapy”[MeSH] OR “Cognitive Therapy”[MeSH] OR “Time Management”[MeSH] OR “Computer-Assisted Instruction”[MeSH] OR “Diet Therapy”[MeSH] OR “Fatty Acids, Omega-3/therapeutic use”[MeSH] OR “Vitamins/administration and dosage”[Mesh] OR “Vitamins/therapeutic use”[MeSH] OR “Food Additives/adverse effects”[MeSH] OR “Probiotics/therapeutic use”[MeSH] OR “Acupuncture Therapy”[MeSH] OR “Remedial Teaching”[MeSH] OR “Early Intervention (Education)”[MeSH] OR “Complementary Therapies”[MeSH] OR “Combined Modality Therapy”[MeSH] OR “psychosocial therapy”[tiab] OR “psychosocial intervention”[tiab] OR “psychosocial interventions”[tiab] OR “psychosocial approach”[tiab] OR “psychosocial approaches”[tiab] OR “psychosocial treatment”[tiab] OR “psychosocial support”[tiab] OR “psychoeducation”[tiab] OR “nonpharmacologic therapy”[tiab] OR “nondrug therapy”[tiab] OR “non-drug therapy”[tiab] OR “Play Therapy”[tiab] OR “cognitive behavioral therapy”[tiab] OR “cognitive behavior therapy”[tiab] OR “cognitive behavioural therapy”[tiab] OR “cognitive behaviour therapy”[tiab] OR Mindfulness[tiab] OR complementary[tiab] OR “alternative medicine”[tiab] OR “alternative therapy”[tiab] OR “alternative therapies”[tiab] OR “Interpersonal skills training”[tiab] OR “Parent-Child Interaction Therapy”[tiab] OR “parent training”[tiab] OR “parent engagement”[tiab] OR “parent management”[tiab] OR “parenting skills”[tiab] OR “parenting intervention”[tiab] OR “parenting interventions”[tiab] OR “Barkley’s defiant child”[tiab] OR “Teacher-Child Interaction Training”[tiab] OR “Incredible Years”[tiab] OR “New Forest Parenting”[tiab] OR “Triple P”[tiab] OR “Helping the Noncompliant Child”[tiab] OR “child life and attention skills”[tiab] OR “clas”[tiab] OR PCIT[tiab] OR “parent child interaction therapy”[tiab] OR “Summer Treatment Program”[tiab] OR “Daily Report Card”[tiab] OR “organization skills”[tiab] OR “organizational skills”[tiab] OR “time management”[tiab] OR “homework intervention”[tiab] OR braintrain[tiab] OR “memory training”[tiab] OR “Captain’s log mindpower builder”[tiab] OR “memory gyms”[tiab] OR “attention gym”[tiab] OR “smartdriver plus”[tiab] OR “smartmind pro”[tiab] OR “RoboMemo”[tiab] OR “play attention”[tiab] OR metronome[tiab] OR brainmaster[tiab] OR mindmed[tiab] OR “attention lab”[tiab] OR (activate[tiab] AND c8[tiab]) OR “attention training”[tiab] OR “CogniPlus”[tiab] OR cogmed[tiab] OR “working memory training”[tiab] OR biofeedback[tiab] OR neurofeedback[tiab] OR neuroagility[tiab] OR neuroptimal[tiab] OR acupuncture[tiab] OR “vision training”[tiab] OR “visual training”[tiab] OR “vision therapy”[tiab] OR “education intervention”[tiab] OR “cognitive remediation”[tiab] OR neurotherapy[tiab] OR “elimination diet”[tiab] OR “diet therapy”[tiab] OR ((“low carb” OR “low carbohydrate” OR “low carbohydrates”[tiab] OR “gluten free”) AND diet[tiab]) OR “feingold diet”[tiab] OR “red dye”[tiab] OR ((vitamin[tiab] OR vitamins[tiab]) AND (supplement[tiab] OR supplements[tiab])) OR “herbal supplement”[tiab] OR “herbal supplements”[tiab] OR probiotics[tiab] OR “omega 3”[tiab] OR “slow cortical potentials”[tiab] OR “few foods diet”[tiab] OR “oligoantigenic diet”[tiab] OR “restriction diet”[tiab] OR “food intolerance”[tiab] OR “food allergy”[tiab] OR “food allergies”[tiab] OR “food sensitivity”[tiab] OR “food sensitivities”[tiab] OR “multimodal treatment”[tiab] OR homeopathy[tiab] OR homeopathic[tiab] OR chiropractic[tiab] OR chiropractor[tiab]
#6 | #4 OR #5
#7 | #3 AND #6
#8 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR “evaluation studies”[pt] OR “evaluation studies as topic”[MeSH] OR “evaluation study”[tiab] OR “evaluation studies”[tiab] OR “intervention studies”[MeSH] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “case-control studies”[MeSH] OR “case-control”[tiab] OR “cohort studies”[MeSH] OR cohort[tiab] OR “longitudinal”[tiab] OR longitudinally[tiab] OR “prospective”[tiab] OR prospectively[tiab] OR “retrospective”[tiab] OR “comparative study”[pt] OR “comparative study”[tiab] OR systematic[sb] OR “meta-analysis”[pt] OR “meta-analysis as topic”[MeSH] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab]) NOT (Editorial[ptyp] OR Letter[pt] OR Case Reports[pt] OR Comment[pt]) NOT (animals[mh] NOT humans[mh]) AND English[la]
#9 | #7 AND #8
| Publication date from 2009/01/01

### Key Question 3

Set # | Terms
#1 | “Attention Deficit Disorder with Hyperactivity”[Mesh] OR “attention deficit hyperactivity disorder”[tiab] OR “ADHD”[tiab] OR “attention deficit disorder”[tiab]
#2 | “Pediatrics”[Mesh] OR “Adolescent”[Mesh] OR “Infant”[Mesh] OR “Child”[Mesh] OR child[tiab] OR children[tiab] OR infant[tiab] OR infants[tiab] OR preschool[tiab] OR preschooler[tiab] OR pediatric[tiab] OR teenager[tiab] OR teenagers[tiab] OR teenaged[tiab] OR teen[tiab] OR teens[tiab] OR adolescent[tiab] OR adolescents[tiab] OR adolescence[tiab] OR youth[tiab]
#3 | “Secondary Care”[Mesh] OR “Comprehensive Health Care”[Mesh] OR “primary care”[tiab] OR monitor[tiab] OR monitored[tiab] OR monitoring[tiab] OR “follow up”[tiab] OR “followed up”[tiab] OR visit[tiab] OR visits[tiab] OR session[tiab] OR sessions[tiab] OR appointment[tiab] OR appointments[tiab]
#4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tiab] OR “clinical trials”[tiab] OR “evaluation studies”[pt] OR “evaluation studies as topic”[MeSH] OR “evaluation study”[tiab] OR “evaluation studies”[tiab] OR “intervention studies”[MeSH] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “case-control studies”[MeSH] OR “case-control”[tiab] OR “cohort studies”[MeSH] OR cohort[tiab] OR “longitudinal”[tiab] OR longitudinally[tiab] OR “prospective”[tiab] OR prospectively[tiab] OR “retrospective”[tiab] OR “comparative study”[pt] OR “comparative study”[tiab] OR systematic[sb] OR “meta-analysis”[pt] OR “meta-analysis as topic”[MeSH] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab]) NOT (Editorial[ptyp] OR Letter[pt] OR Case Reports[pt] OR Comment[pt]) NOT (animals[mh] NOT humans[mh]) AND English[la]
#5 | #1 AND #2 AND #3 AND #4
| Publication date from 2009/01/01

## Embase^®^ Search Strategy (November 7, 2016)

Platform: Embase.com

### Key Question 1

Set # | Terms
#1 | ‘attention deficit disorder’/exp OR “attention deficit hyperactivity disorder”:ab,ti OR “ADHD”:ab,ti OR “attention deficit disorder”:ab,ti
#2 | ‘pediatrics’/exp OR ‘adolescent’/exp OR ‘infant’/exp OR ‘child’/exp OR child:ab,ti OR children:ab,ti OR infant:ab,ti OR infants:ab,ti OR preschool:ab,ti OR preschooler:ab,ti OR pediatric:ab,ti OR teenager:ab,ti OR teenagers:ab,ti OR teenaged:ab,ti OR teen:ab,ti OR teens:ab,ti OR adolescent:ab,ti OR adolescents:ab,ti OR adolescence:ab,ti OR youth:ab,ti
#3 | ‘attention deficit disorder’/exp/mj/dm_di OR ‘screening’/exp OR ‘questionnaire’/exp OR ‘interview’/exp OR ‘psychometry’/exp OR ‘psychological rating scale’/exp OR ‘diagnosis’/exp OR ‘assessment of humans’/exp OR ‘checklist’/exp OR ‘clinical assessment tool’/exp OR ‘clinical observation’/exp OR ‘Diagnostic and Statistical Manual of Mental Disorders’/exp OR ‘patient referral’/exp OR questionnaire:ab,ti OR questionnaires:ab,ti OR screening:ab,ti OR screen:ab,ti OR scale:ab,ti OR instrument:ab,ti OR instruments:ab,ti OR interview:ab,ti OR interviews:ab,ti OR DSM*:ab,ti OR diagnosis:ab,ti OR diagnostic:ab,ti OR diagnosed:ab,ti OR (Vanderbilt:ab,ti AND scale:ab,ti) OR conners:ab,ti OR cprs:ab,ti OR ctrs:ab,ti OR cprs:ab,ti OR crs:ab,ti OR “snap-IV”:ab,ti OR “snap-4”:ab,ti OR “basc-2”:ab,ti OR “behavioral assessment system for children”:ab,ti OR dbdrs:ab,ti OR “disruptive behavior disorder rating scale”:ab,ti OR adhd-rs:ab,ti OR “adhd rating scale”:ab,ti OR ksads:ab,ti OR k-sads:ab,ti OR kiddie-sads:ab,ti OR DISC:ab,ti OR “dominance inducement submission and compliance”:ab,ti OR “diagnostic interview schedule for children”:ab,ti OR “diagnostic inventory for screening children”:ab,ti OR “mini-kid”:ab,ti OR “Mini Interational Neuropsychiatric interview”:ab,ti OR “iva-2”:ab,ti OR “iva-qs”:ab,ti OR “iva-ae2”:ab,ti OR tova:ab,ti OR “test of variables of attention”:ab,ti OR “neuropsychiatric eeg-based assessment aid”:ab,ti OR neba:ab,ti
#4 | (‘sensitivity and specificity’/exp OR ‘predictive value’/exp OR ‘diagnostic error’/exp OR sensitivity:ab,ti OR specificity:ab,ti OR accuracy:ab,ti OR accurate:ab,ti OR accurately:ab,ti OR misdiagnos*:ab,ti OR ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 AND [embase]/lim NOT [medline]/lim
#7 | #6 AND [humans]/lim AND [2009–2015]/py

### Key Question 2

Set # | Terms
#1 | ‘attention deficit disorder’/exp OR “attention deficit hyperactivity disorder”:ab,ti OR “ADHD”:ab,ti OR “attention deficit disorder”:ab,ti
#2 | ‘pediatrics’/exp OR ‘adolescent’/exp OR ‘infant’/exp OR ‘child’/exp OR child:ab,ti OR children:ab,ti OR infant:ab,ti OR infants:ab,ti OR preschool:ab,ti OR preschooler:ab,ti OR pediatric:ab,ti OR teenager:ab,ti OR teenagers:ab,ti OR teenaged:ab,ti OR teen:ab,ti OR teens:ab,ti OR adolescent:ab,ti OR adolescents:ab,ti OR adolescence:ab,ti OR youth:ab,ti
#3 | #1 AND #2
#4 | ‘attention deficit disorder’/exp/mj/dm_dt OR ‘central stimulant agent’/exp OR ‘psychostimulant agent’/exp OR ‘guanfacine’/exp OR ‘adrenergic receptor affecting agent’/exp OR ‘atomoxetine’/exp OR ‘antidepressant agent’/exp OR ‘dopamine uptake inhibitor’/exp OR ‘n methyl dextro aspartic acid receptor’/exp OR ‘memantine’/exp OR ‘amantadine’/exp OR ‘dopamine uptake inhibitor’/exp OR ‘Central Nervous System Stimulants’:ab,ti OR ‘psychostimulant’:ab,ti OR ‘Methylphenidate’:ab,ti OR ‘Methylphenidate Hydrochloride’:ab,ti OR ‘Aptensio’:ab,ti OR ‘Concerta’:ab,ti OR ‘Ritalin’:ab,ti OR ‘Ritalin LA’:ab,ti OR ‘Medikinet’:ab,ti OR ‘Equasym’:ab,ti OR ‘Quillivant’:ab,ti OR ‘Metadate’:ab,ti OR ‘Daytrana’:ab,ti OR ‘Dexmethylphenidate’:ab,ti OR ‘Dexmethylphenidate Hydrochloride’:ab,ti OR ‘Focalin’:ab,ti OR ‘Dextroamphetamine’:ab,ti OR ‘Dexedrine’:ab,ti OR ‘Dextrostat’:ab,ti OR ‘ProCentra’:ab,ti OR ‘Zenzedi’:ab,ti OR ‘mixed amphetamine salts’:ab,ti OR ‘Adderall’:ab,ti OR ‘lisdexamfetamine’:ab,ti OR ‘lisdexamfetamine dimesylate’:ab,ti OR ‘Vyvanse’:ab,ti OR ‘Venvanse’:ab,ti OR ‘Elvanse’:ab,ti OR ‘Tyvense’:ab,ti OR ‘Dyanavel’:ab,ti OR ‘Evekeo’:ab,ti OR ‘Guanfacine’:ab,ti OR ‘Sympatholytics’:ab,ti OR ‘Central alpha-2 Adrenergic Agonist’:ab,ti OR ‘Clonidine’:ab,ti OR ‘Intuniv’:ab,ti OR ‘Estulic’:ab,ti OR ‘Tenex’:ab,ti OR ‘Catapres’:ab,ti OR ‘Clophelin’:ab,ti OR ‘Kapvay’:ab,ti OR ‘Nexiclon’:ab,ti OR ‘Duraclon’:ab,ti OR ‘Norepinephrine Reuptake Inhibitors’:ab,ti OR ‘Selective Norepinephrine Reuptake Inhibitors’:ab,ti OR ‘Adrenergic Uptake Inhibitors’:ab,ti OR ‘atomoxetine’:ab,ti OR ‘Strattera’:ab,ti OR ‘Tricyclic antidepressants’:ab,ti OR ‘Desipramine’:ab,ti OR ‘Norpramin’:ab,ti OR ‘Nortriptyline’:ab,ti OR ‘Pamelor’:ab,ti OR ‘Dopamine Reuptake Inhibitors’:ab,ti OR ‘modafinil’:ab,ti OR ‘Provigil’:ab,ti OR ‘Armodafinil’:ab,ti OR ‘Norepinephrine-dopamine Reuptake Inhibitors’:ab,ti OR ‘Bupropion’:ab,ti OR ‘Wellbutrin’:ab,ti OR ‘Forfivo’:ab,ti OR ‘Cymbalta’:ab,ti OR ‘venlafaxine’:ab,ti OR ‘reboxetine’:ab,ti OR ‘Monoamine Oxidase Type B inhibitors’:ab,ti OR ‘Selegiline’:ab,ti OR ‘Eldepryl’:ab,ti OR ‘Zelapar’:ab,ti OR ‘NMDA receptors’:ab,ti OR ‘N-Methyl-D-aspartate receptor Antagonists’:ab,ti OR ‘Amantadine’:ab,ti OR ‘Memantine’:ab,ti OR ‘Pertofrane’:ab,ti OR ‘Nuvigil’:ab,ti OR ‘Cymbalta’:ab,ti OR ‘duloxetine’:ab,ti OR ‘Effexor’:ab,ti OR ‘Eldepryl’:ab,ti OR ‘Emsam’:ab,ti OR ‘Trevilor’:ab,ti OR ‘Symmetrel’:ab,ti OR ‘Namenda’:ab,ti OR ‘Zelapar’:ab,ti
#5 | ‘attention deficit disorder’/exp/mj/dm_rh,dm_dm OR ‘psychotherapy’/exp OR ‘child psychiatry’/exp OR ‘child parent relation’/exp OR ‘time management’/exp OR ‘feedback system’/exp OR ‘teaching’/exp OR ‘adaptive behavior’/exp OR ‘diet therapy’/exp OR ‘omega 3 fatty acid’/exp OR ‘vitamin’/exp/dd_do,dd_dt,dd_ad OR ‘food additive’/exp/dd_ae OR ‘probiotic agent’/exp OR ‘acupuncture’/exp OR ‘early childhood intervention’/exp OR ‘alternative medicine’/exp OR ‘psychosocial therapy’:ab,ti OR ‘psychosocial intervention’:ab,ti OR ‘psychosocial interventions’:ab,ti OR ‘psychosocial approach’:ab,ti OR ‘psychosocial approaches’:ab,ti OR ‘psychosocial treatment’:ab,ti OR ‘psychosocial support’:ab,ti OR ‘psychoeducation’:ab,ti OR ‘nonpharmacologic therapy’:ab,ti OR ‘nondrug therapy’:ab,ti OR ‘non-drug therapy’:ab,ti OR ‘Play Therapy’:ab,ti OR ‘cognitive behavioral therapy’:ab,ti OR ‘cognitive behavior therapy’:ab,ti OR ‘cognitive behavioural therapy’:ab,ti OR ‘cognitive behaviour therapy’:ab,ti OR Mindfulness:ab,ti OR complementary:ab,ti OR ‘alternative medicine’:ab,ti OR ‘alternative therapy’:ab,ti OR ‘alternative therapies’:ab,ti OR ‘Interpersonal skills training’:ab,ti OR ‘Parent-Child Interaction Therapy’:ab,ti OR ‘parent training’:ab,ti OR ‘parent engagement’:ab,ti OR ‘parent management’:ab,ti OR ‘parenting skills’:ab,ti OR ‘parenting intervention’:ab,ti OR ‘parenting interventions’:ab,ti OR ‘Barkleys defiant child’:ab,ti OR ‘Teacher-Child Interaction Training’:ab,ti OR ‘Incredible Years’:ab,ti OR ‘New Forest Parenting’:ab,ti OR ‘Triple P’:ab,ti OR ‘Helping the Noncompliant Child’:ab,ti OR ‘child life and attention skills’:ab,ti OR ‘clas’:ab,ti OR PCIT:ab,ti OR ‘parent child interaction therapy’:ab,ti OR ‘Summer Treatment Program’:ab,ti OR ‘Daily Report Card’:ab,ti OR ‘organization skills’:ab,ti OR ‘organizational skills’:ab,ti OR ‘time management’:ab,ti OR ‘homework intervention’:ab,ti OR braintrain:ab,ti OR ‘memory training’:ab,ti OR ‘Captains log mindpower builder’:ab,ti OR ‘memory gyms’:ab,ti OR ‘attention gym’:ab,ti OR ‘smartdriver plus’:ab,ti OR ‘smartmind pro’:ab,ti OR ‘RoboMemo’:ab,ti OR ‘play attention’:ab,ti OR metronome:ab,ti OR brainmaster:ab,ti OR mindmed:ab,ti OR ‘attention lab’:ab,ti OR (activate:ab,ti AND c8:ab,ti) OR ‘attention training’:ab,ti OR ‘CogniPlus’:ab,ti OR cogmed:ab,ti OR ‘working memory training’:ab,ti OR biofeedback:ab,ti OR neurofeedback:ab,ti OR neuroagility:ab,ti OR neuroptimal:ab,ti OR acupuncture:ab,ti OR ‘vision training’:ab,ti OR ‘visual training’:ab,ti OR ‘vision therapy’:ab,ti OR ‘education intervention’:ab,ti OR ‘cognitive remediation’:ab,ti OR neurotherapy:ab,ti OR ‘elimination diet’:ab,ti OR ‘diet therapy’:ab,ti OR ((‘low carb’ OR ‘low carbohydrate’ OR ‘low carbohydrates’:ab,ti OR ‘gluten free’) AND diet:ab,ti) OR ‘feingold diet’:ab,ti OR ‘red dye’:ab,ti OR ((vitamin:ab,ti OR vitamins:ab,ti) AND (supplement:ab,ti OR supplements:ab,ti)) OR ‘herbal supplement’:ab,ti OR ‘herbal supplements’:ab,ti OR probiotics:ab,ti OR ‘omega 3’:ab,ti OR ‘slow cortical potentials’:ab,ti OR ‘few foods diet’:ab,ti OR ‘oligoantigenic diet’:ab,ti OR ‘restriction diet’:ab,ti OR ‘food intolerance’:ab,ti OR ‘food allergy’:ab,ti OR ‘food allergies’:ab,ti OR ‘food sensitivity’:ab,ti OR ‘food sensitivities’:ab,ti OR ‘multimodal treatment’:ab,ti OR homeopathy:ab,ti OR homeopathic:ab,ti OR chiropractic:ab,ti OR chiropractor:ab,ti
#6 | #4 OR #5
#7 | #3 AND #6
#8 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#9 | #7 AND #8
#10 | #9 AND [embase]/lim NOT [medline]/lim
#11 | #10 AND [humans]/lim AND [2009–2015]/py

### Key Question 3

Set # | Terms
#1 | ‘attention deficit disorder’/exp OR “attention deficit hyperactivity disorder”:ab,ti OR “ADHD”:ab,ti OR “attention deficit disorder”:ab,ti
#2 | ‘pediatrics’/exp OR ‘adolescent’/exp OR ‘infant’/exp OR ‘child’/exp OR child:ab,ti OR children:ab,ti OR infant:ab,ti OR infants:ab,ti OR preschool:ab,ti OR preschooler:ab,ti OR pediatric:ab,ti OR teenager:ab,ti OR teenagers:ab,ti OR teenaged:ab,ti OR teen:ab,ti OR teens:ab,ti OR adolescent:ab,ti OR adolescents:ab,ti OR adolescence:ab,ti OR youth:ab,ti
#3 | ‘evaluation and follow up’/exp OR ‘primary health care’/exp OR ‘secondary health care’/exp OR ‘clinical handover’/exp OR ‘patient monitoring’/exp OR monitor:ab,ti OR monitored:ab,ti OR monitoring:ab,ti OR “follow up”:ab,ti OR “followed up”:ab,ti OR visit:ab,ti OR visits:ab,ti OR session:ab,ti OR sessions:ab,ti OR appointment:ab,ti OR appointments:ab,ti
#4 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti OR ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 AND [humans]/lim AND [2009–2015]/py
#7 | #6 AND [embase]/lim NOT [medline]/lim

## PsycInfo Search Strategy (November 7, 2016)

### Key Question 1

Set # | Terms
#1 | DE “Attention Deficit Disorder with Hyperactivity” OR TI ( “attention deficit hyperactivity disorder” OR ADHD OR “attention deficit disorder” ) OR AB ( “attention deficit hyperactivity disorder” OR ADHD OR “attention deficit disorder”
#2 | AG (childhood OR adolescence ) OR DE “Pediatrics” OR TI ( child OR children OR infant OR infants OR preschool OR preschooler OR pediatric OR teenager OR teenagers OR teenaged OR teen OR teens OR adolescent OR adolescents OR adolescence OR youth ) OR AB ( child OR children OR infant OR infants OR preschool OR preschooler OR pediatric OR teenager OR teenagers OR teenaged OR teen OR teens OR adolescent OR adolescents OR adolescence OR youth )
#3 | DE “Screening” OR DE “Health Screening” OR DE “Questionnaires” OR DE “Screening Tests” OR DE “Psychological Screening Inventory” OR DE “Psychiatric Evaluation” OR DE “Psychodiagnosis” OR DE “Psychodiagnostic Interview” OR DE “Psychometrics” OR DE “Rating Scales” OR DE “Diagnosis” OR DE “Diagnostic and Statistical Manual” OR DE “Professional Referral” OR DE “Diagnostic Interview Schedule” OR DE “Behavioral Assessment” OR TI ( questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR interview OR interviews OR DSM* OR diagnosis OR diagnostic OR diagnosed OR (Vanderbilt AND scale) OR conners OR cprs OR ctrs OR cprs OR crs OR “snap-IV” OR “snap-4” OR “basc-2” OR “behavioral assessment system for children” OR dbdrs OR “disruptive behavior disorder rating scale” OR adhd-rs OR “adhd rating scale” OR ksads OR k-sads OR kiddie-sads OR DISC OR “dominance inducement submission and compliance” OR “diagnostic interview schedule for children” OR “diagnostic inventory for screening children” OR “mini-kid” OR “Mini Interational Neuropsychiatric interview” OR “iva-2” OR “iva-qs” OR “iva-ae2” OR tova OR “test of variables of attention” OR “neuropsychiatric eeg-based assessment aid” OR neba ) OR AB ( questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR interview OR interviews OR DSM* OR diagnosis OR diagnostic OR diagnosed OR (Vanderbilt AND scale) OR conners OR cprs OR ctrs OR cprs OR crs OR “snap-IV” OR “snap-4” OR “basc-2” OR “behavioral assessment system for children” OR dbdrs OR “disruptive behavior disorder rating scale” OR adhd-rs OR “adhd rating scale” OR ksads OR k-sads OR kiddie-sads OR DISC OR “dominance inducement submission and compliance” OR “diagnostic interview schedule for children” OR “diagnostic inventory for screening children” OR “mini-kid” OR “Mini Interational Neuropsychiatric interview” OR “iva-2” OR “iva-qs” OR “iva-ae2” OR tova OR “test of variables of attention” OR “neuropsychiatric eeg-based assessment aid” OR neba )
#4 | (DE “Misdiagnosis” OR ZC “longitudinal study” OR ZC “empirical study” OR ZC “followup study” OR ZC “longitudinal study” OR ZC “meta analysis” OR ZC “prospective study” OR ZC “retrospective study” OR ZC “systematic review” OR ZC “treatment outcome/clinical trial”OR DE “Clinical Trials” OR DE “Cohort Analysis” OR DE “Followup Studies” OR DE “Longitudinal Studies” OR DE “Prospective Studies” OR DE “Meta Analysis” OR TI ( sensitivity OR specificity OR accuracy OR accurate OR accurately OR misdiagnos* OR randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials OR “evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR “cross-sectional” OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study” OR “meta-analysis” OR “meta-analyses” ) OR AB ( sensitivity OR specificity OR accuracy OR accurate OR accurately OR misdiagnos* OR randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials OR “evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR “cross-sectional” OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study” OR “meta-analysis” OR “meta-analyses” )) AND (ZZ “journal article”)
#5 | #1 AND #2 AND #3 AND #4
#6 | #5, since 2009, English

### Key Question 2

Set # | Terms
#1 | DE “Attention Deficit Disorder with Hyperactivity” OR TI ( “attention deficit hyperactivity disorder” OR ADHD OR “attention deficit disorder” ) OR AB ( “attention deficit hyperactivity disorder” OR ADHD OR “attention deficit disorder”
#2 | AG (childhood OR adolescence ) OR DE “Pediatrics” OR TI ( child OR children OR infant OR infants OR preschool OR preschooler OR pediatric OR teenager OR teenagers OR teenaged OR teen OR teens OR adolescent OR adolescents OR adolescence OR youth ) OR AB ( child OR children OR infant OR infants OR preschool OR preschooler OR pediatric OR teenager OR teenagers OR teenaged OR teen OR teens OR adolescent OR adolescents OR adolescence OR youth )
#3 | #1 AND #2
#4 | DE “CNS Stimulating Drugs” OR DE “Methylphenidate” OR DE “Dextroamphetamine” OR DE “Amphetamine” OR DE “Clonidine” OR DE “Serotonin Norepinephrine Reuptake Inhibitors” OR DE “Atomoxetine” OR DE “Tricyclic Antidepressant Drugs” OR DE “Desipramine” OR DE “Nortriptyline” OR DE “Bupropion” OR DE “Serotonin Norepinephrine Reuptake Inhibitors” OR DE “Venlafaxine” OR DE “Monoamine Oxidase Inhibitors” OR DE “Amantadine” OR TI ( psychostimulants OR “CNS stimulating” OR “Central Nervous System stimulants” OR methylphenidate OR Dexmethylphenidate OR Dextroamphetamine OR lisdexamfetamine OR Amphetamine OR aptensio OR concerta OR Ritalin OR methylin OR medikinet OR equasym OR quillivant OR metadate OR daytrana OR focalin OR Dexedrine OR dextrostat OR procentra OR zenzedi OR Adderall OR vyvanse OR elvanse OR tyvense OR dyanavel OR evekeo OR “alpha-2 agonists” OR guanfacine OR intuniv OR tenex OR estulic OR afken OR clonidine OR catapres OR clophelin OR kapvay OR nexiclon OR duraclon OR “Serotonin Norepinephrine Reuptake Inhibitors” OR Strattera OR atomoxetine OR “Tricyclic Antidepressants “ OR “Desipramine” OR “Nortriptyline” OR norpramin OR pertofrane OR pamelor OR “dopamine reuptake inhibitors” OR modanifil OR Provigil OR alertec OR modavigil OR modiodal OR modalert OR armodafinil OR nuvigil OR “norepinephrine-dopamine reuptake inhibitors” OR bupropion OR Wellbutrin OR zyban OR forfivo OR “Serotonin Norepinephrine Reuptake Inhibitors” OR duloxetine OR Cymbalta OR “serotonin norepinephrine dopamine reuptake inhibitors” OR “Venlafaxine” OR Effexor OR trevilor OR (Monoamine Oxidase AND Inhibitors) OR selegiline OR eldepryl OR emsam OR selgene OR zelapar OR “n methyl d aspartate receptor agonists” OR “Amantadine” OR symmetrel OR memantine OR Namenda) ) OR AB ( psychostimulants OR “CNS stimulating” OR “Central Nervous System stimulants” OR methylphenidate OR Dexmethylphenidate OR Dextroamphetamine OR lisdexamfetamine OR Amphetamine OR aptensio OR concerta OR Ritalin OR methylin OR medikinet OR equasym OR quillivant OR metadate OR daytrana OR focalin OR Dexedrine OR dextrostat OR procentra OR zenzedi OR Adderall OR vyvanse OR elvanse OR tyvense OR dyanavel OR evekeo OR “alpha-2 agonists” OR guanfacine OR intuniv OR tenex OR estulic OR afken OR clonidine OR catapres OR clophelin OR kapvay OR nexiclon OR duraclon OR “Serotonin Norepinephrine Reuptake Inhibitors” OR Strattera OR atomoxetine OR “Tricyclic Antidepressants “ OR “Desipramine” OR “Nortriptyline” OR norpramin OR pertofrane OR pamelor OR “dopamine reuptake inhibitors” OR modanifil OR Provigil OR alertec OR modavigil OR modiodal OR modalert OR armodafinil OR nuvigil OR “norepinephrine-dopamine reuptake inhibitors” OR bupropion OR Wellbutrin OR zyban OR forfivo OR “Serotonin Norepinephrine Reuptake Inhibitors” OR duloxetine OR Cymbalta OR “serotonin norepinephrine dopamine reuptake inhibitors” OR “Venlafaxine” OR Effexor OR trevilor OR (Monoamine Oxidase AND Inhibitors) OR selegiline OR eldepryl OR emsam OR selgene OR zelapar OR “n methyl d aspartate receptor agonists” OR “Amantadine” OR symmetrel OR memantine OR Namenda) )
#5 | DE “Psychotherapy” OR DE “Adolescent Psychotherapy” OR DE “Multisystemic Therapy” OR DE “Behavior Therapy” OR DE “Dialectical Behavior Therapy” OR DE “Brief Psychotherapy” OR DE “Child Psychotherapy” OR DE “Play Therapy” OR DE “Client Centered Therapy” OR DE “Cognitive Behavior Therapy” OR DE “Group Psychotherapy” OR DE “Therapeutic Community” OR DE “Integrative Psychotherapy” OR DE “Psychotherapeutic Counseling” OR DE “Family Therapy” OR DE “Supportive Psychotherapy” OR DE “Cognitive Therapy” OR DE “Parent Training” OR DE “Parent Child Relations” OR DE “Time Management” OR DE “Mindfulness” OR DE “School Based Intervention” OR DE “Memory Training” OR DE “Biofeedback Training” OR DE “Biofeedback” OR DE “Computer Assisted Instruction” OR DE “Intelligent Tutoring Systems” OR DE “Diets” OR DE “Dietary Supplements” OR DE “Food Additives” OR DE “Fatty Acids” OR DE “Acupuncture” OR DE “Remedial Education” OR DE “Early Intervention” OR DE “Alternative Medicine” OR TI ( “psychosocial therapy” OR “psychosocial intervention” OR “psychosocial interventions” OR “psychosocial approach” OR “psychosocial approaches” OR “psychosocial treatment” OR “psychosocial support” OR “psychoeducation” OR “nonpharmacologic therapy” OR “nondrug therapy” OR “non-drug therapy” OR “Play Therapy” OR “cognitive behavioral therapy” OR “cognitive behavior therapy” OR “cognitive behavioural therapy” OR “cognitive behaviour therapy” OR Mindfulness OR complementary OR “alternative medicine” OR “alternative therapy” OR “alternative therapies” OR “Interpersonal skills training” OR “Parent-Child Interaction Therapy” OR “parent training” OR “parent engagement” OR “parent management” OR “parenting skills” OR “parenting intervention” OR “parenting interventions” OR “Barkley’s defiant child” OR “Teacher-Child Interaction Training” OR “Incredible Years” OR “New Forest Parenting” OR “Triple P” OR “Helping the Noncompliant Child” OR “child life and attention skills” OR “clas” OR PCIT OR “parent child interaction therapy” OR “Summer Treatment Program” OR “Daily Report Card” OR “organization skills” OR “organizational skills” OR “time management” OR “homework intervention” OR braintrain OR “memory training” OR “Captain’s log mindpower builder” OR “memory gyms” OR “attention gym” OR “smartdriver plus” OR “smartmind pro” OR “RoboMemo” OR “play attention” OR metronome OR brainmaster OR mindmed OR “attention lab” OR (activate AND c8) OR “attention training” OR “CogniPlus” OR cogmed OR “working memory training” OR biofeedback OR neurofeedback OR neuroagility OR neuroptimal OR acupuncture OR “vision training” OR “visual training” OR “vision therapy” OR “education intervention” OR “cognitive remediation” OR neurotherapy OR “elimination diet” OR “diet therapy” OR ((“low carb” OR “low carbohydrate” OR “low carbohydrates” OR “gluten free”) AND diet) OR “feingold diet” OR “red dye” OR ((vitamin OR vitamins) AND (supplement OR supplements)) OR “herbal supplement” OR “herbal supplements” OR probiotics OR “omega 3” OR “slow cortical potentials” OR “few foods diet” OR “oligoantigenic diet” OR “restriction diet” OR “food intolerance” OR “food allergy” OR “food allergies” OR “food sensitivity” OR “food sensitivities” OR “multimodal treatment” OR homeopathy OR homeopathic OR chiropractic OR chiropractor ) OR AB ( “psychosocial therapy” OR “psychosocial intervention” OR “psychosocial interventions” OR “psychosocial approach” OR “psychosocial approaches” OR “psychosocial treatment” OR “psychosocial support” OR “psychoeducation” OR “nonpharmacologic therapy” OR “nondrug therapy” OR “non-drug therapy” OR “Play Therapy” OR “cognitive behavioral therapy” OR “cognitive behavior therapy” OR “cognitive behavioural therapy” OR “cognitive behaviour therapy” OR Mindfulness OR complementary OR “alternative medicine” OR “alternative therapy” OR “alternative therapies” OR “Interpersonal skills training” OR “Parent-Child Interaction Therapy” OR “parent training” OR “parent engagement” OR “parent management” OR “parenting skills” OR “parenting intervention” OR “parenting interventions” OR “Barkley’s defiant child” OR “Teacher-Child Interaction Training” OR “Incredible Years” OR “New Forest Parenting” OR “Triple P” OR “Helping the Noncompliant Child” OR “child life and attention skills” OR “clas” OR PCIT OR “parent child interaction therapy” OR “Summer Treatment Program” OR “Daily Report Card” OR “organization skills” OR “organizational skills” OR “time management” OR “homework intervention” OR braintrain OR “memory training” OR “Captain’s log mindpower builder” OR “memory gyms” OR “attention gym” OR “smartdriver plus” OR “smartmind pro” OR “RoboMemo” OR “play attention” OR metronome OR brainmaster OR mindmed OR “attention lab” OR (activate AND c8) OR “attention training” OR “CogniPlus” OR cogmed OR “working memory training” OR biofeedback OR neurofeedback OR neuroagility OR neuroptimal OR acupuncture OR “vision training” OR “visual training” OR “vision therapy” OR “education intervention” OR “cognitive remediation” OR neurotherapy OR “elimination diet” OR “diet therapy” OR ((“low carb” OR “low carbohydrate” OR “low carbohydrates” OR “gluten free”) AND diet) OR “feingold diet” OR “red dye” OR ((vitamin OR vitamins) AND (supplement OR supplements)) OR “herbal supplement” OR “herbal supplements” OR probiotics OR “omega 3” OR “slow cortical potentials” OR “few foods diet” OR “oligoantigenic diet” OR “restriction diet” OR “food intolerance” OR “food allergy” OR “food allergies” OR “food sensitivity” OR “food sensitivities” OR “multimodal treatment” OR homeopathy OR homeopathic OR chiropractic OR chiropractor )
6 | #4 OR #5
7 | #3 AND #6
8 | ZC “longitudinal study” OR ZC “empirical study” OR ZC “followup study” OR ZC “longitudinal study” OR ZC “meta analysis” OR ZC “prospective study” OR ZC “retrospective study” OR ZC “systematic review” OR ZC “treatment outcome/clinical trial”OR DE “Clinical Trials” OR DE “Cohort Analysis” OR DE “Followup Studies” OR DE “Longitudinal Studies” OR DE “Prospective Studies” OR DE “Meta Analysis” OR TI (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials OR “evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study” OR “meta-analysis” OR “meta-analyses” ) OR AB (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials OR “evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study” OR “meta-analysis” OR “meta-analyses” ) AND (ZZ “journal article”)
9 | #7 AND #8
10 | #9, since 2009

### Key Question 3

Set # | Terms
#1 | DE “Attention Deficit Disorder with Hyperactivity” OR TI ( “attention deficit hyperactivity disorder” OR ADHD OR “attention deficit disorder” ) OR AB ( “attention deficit hyperactivity disorder” OR ADHD OR “attention deficit disorder”
#2 | AG (childhood OR adolescence ) OR DE “Pediatrics” OR TI ( child OR children OR infant OR infants OR preschool OR preschooler OR pediatric OR teenager OR teenagers OR teenaged OR teen OR teens OR adolescent OR adolescents OR adolescence OR youth ) OR AB ( child OR children OR infant OR infants OR preschool OR preschooler OR pediatric OR teenager OR teenagers OR teenaged OR teen OR teens OR adolescent OR adolescents OR adolescence OR youth )
#3 | (((((DE “Continuum of Care”) OR (DE “Outpatient Treatment”)) OR (DE “Primary Health Care”)) OR (DE “Monitoring”)) OR (DE “Community Psychiatry”)) OR TI ( “primary care” OR monitor OR monitored OR monitoring OR “follow up” OR “followed up” OR visit OR visits OR session OR sessions OR appointment OR appointments ) OR AB ( “primary care” OR monitor OR monitored OR monitoring OR “follow up” OR “followed up” OR visit OR visits OR session OR sessions OR appointment OR appointments )
#4 | ZC “longitudinal study” OR ZC “empirical study” OR ZC “followup study” OR ZC “longitudinal study” OR ZC “meta analysis” OR ZC “prospective study” OR ZC “retrospective study” OR ZC “systematic review” OR ZC “treatment outcome/clinical trial”OR DE “Clinical Trials” OR DE “Cohort Analysis” OR DE “Followup Studies” OR DE “Longitudinal Studies” OR DE “Prospective Studies” OR DE “Meta Analysis” OR TI (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials OR “evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study” OR “meta-analysis” OR “meta-analyses” ) OR AB (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials OR “evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study” OR “meta-analysis” OR “meta-analyses” ) AND (ZZ “journal article”)
#5 | #1 AND #2 AND #3 AND #4
#6 | #5, since 2009 and English

## Cochrane Search Strategy (November 7, 2016)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

### Key Question 1

Set # | Terms
#1 | [mh “Attention Deficit Disorder with Hyperactivity”]
#2 | “attention deficit hyperactivity disorder”:ab,ti OR “ADHD”:ab,ti OR “attention deficit disorder”:ab,ti
#3 | #1 OR #2
#4 | [mh Pediatrics] OR [mh Adolescent] OR [mh Infant] OR [mh Child]
#5 | child:ab,ti OR children:ab,ti OR infant:ab,ti OR infants:ab,ti OR preschool:ab,ti OR preschooler:ab,ti OR pediatric:ab,ti OR teenager:ab,ti OR teenagers:ab,ti OR teenaged:ab,ti OR teen:ab,ti OR teens:ab,ti OR adolescent:ab,ti OR adolescents:ab,ti OR adolescence:ab,ti OR youth:ab,ti
#6 | #4 OR #5
#7 | [mh “Attention Deficit Disorder with Hyperactivity”/DI] OR [mh “mass screening”] OR [mh questionnaires] OR [mh “Interviews as Topic”] OR [mh Psychometrics] OR [mh “Psychiatric Status Rating Scales”] OR [mh ^diagnosis] OR [mh “Diagnostic Techniques and Procedures”] OR [mh “Diagnostic and Statistical Manual of Mental Disorders”] OR [mh “Referral and Consultation”]
#8 | questionnaire:ab,ti OR questionnaires:ab,ti OR screening:ab,ti OR screen:ab,ti OR scale:ab,ti OR instrument:ab,ti OR instruments:ab,ti OR interview:ab,ti OR interviews:ab,ti OR DSM*:ab,ti OR diagnosis:ab,ti OR diagnostic:ab,ti OR diagnosed:ab,ti OR (Vanderbilt:ab,ti AND scale:ab,ti) OR conners:ab,ti OR cprs:ab,ti OR ctrs:ab,ti OR cprs:ab,ti OR crs:ab,ti OR “snap-IV”:ab,ti OR “snap-4”:ab,ti OR “basc-2”:ab,ti OR “behavioral assessment system for children”:ab,ti OR dbdrs:ab,ti OR “disruptive behavior disorder rating scale”:ab,ti OR adhd-rs:ab,ti OR “adhd rating scale”:ab,ti OR ksads:ab,ti OR k-sads:ab,ti OR kiddie-sads:ab,ti OR DISC:ab,ti OR “dominance inducement submission and compliance”:ab,ti OR “diagnostic interview schedule for children”:ab,ti OR “diagnostic inventory for screening children”:ab,ti OR “mini-kid”:ab,ti OR “Mini Interational Neuropsychiatric interview”:ab,ti OR “iva-2”:ab,ti OR “iva-qs”:ab,ti OR “iva-ae2”:ab,ti OR tova:ab,ti OR “test of variables of attention”:ab,ti OR “neuropsychiatric eeg-based assessment aid”:ab,ti OR neba:ab,ti
#9 | #7 OR #8
#10 | #3 AND #6 AND #9
#11 | #10, since 2009, in CDSR only

### Key Question 2

Set # | Terms
#1 | [mh “Attention Deficit Disorder with Hyperactivity”]
#2 | “attention deficit hyperactivity disorder”:ab,ti OR “ADHD”:ab,ti OR “attention deficit disorder”:ab,ti
#3 | #1 OR #2
#4 | [mh Pediatrics] OR [mh Adolescent] OR [mh Infant] OR [mh Child]
#5 | child:ab,ti OR children:ab,ti OR infant:ab,ti OR infants:ab,ti OR preschool:ab,ti OR preschooler:ab,ti OR pediatric:ab,ti OR teenager:ab,ti OR teenagers:ab,ti OR teenaged:ab,ti OR teen:ab,ti OR teens:ab,ti OR adolescent:ab,ti OR adolescents:ab,ti OR adolescence:ab,ti OR youth:ab,ti
#6 | #4 OR #5
#7 | [mh “Attention Deficit Disorder with Hyperactivity”/DT] OR [mh “Central Nervous System Stimulants”] OR [mh Methylphenidate] OR [mh Dexmethylphenidate] OR [mh Dextroamphetamine] OR [mh Amphetamine] OR [mh Guanfacine] OR [mh Sympatholytics] OR [mh Clonidine] OR [mh “Adrenergic Uptake Inhibitors”] OR [mh “alpha-2 Adrenergic Receptors”] OR [mh “Adrenergic alpha-Agonists”] OR [mh “Adrenergic alpha-2 Receptor Agonists”] OR [mh “Tricyclic Antidepressive Agents”] OR [mh Desipramine] OR [mh “Dopamine Uptake Inhibitors”] OR [mh Sympathomimetics] OR [mh “Serotonin Uptake Inhibitors”] OR [mh “Monoamine Oxidase Inhibitors”] OR [mh “Monoamine Oxidase”] OR [mh Selegiline] OR [mh Bupropion] OR [mh “N-Methyl-D-Aspartate Receptors”] OR [mh Memantine] OR [mh Amantadine]
#8 | “Central Nervous System Stimulants”:ab,ti OR “psychostimulant”:ab,ti OR “Methylphenidate”:ab,ti OR “Methylphenidate Hydrochloride”:ab,ti OR “Aptensio”:ab,ti OR “Concerta”:ab,ti OR “Ritalin”:ab,ti OR “Ritalin LA”:ab,ti OR “Medikinet”:ab,ti OR “Equasym”:ab,ti OR “Quillivant”:ab,ti OR “Metadate”:ab,ti OR “Daytrana”:ab,ti OR “Dexmethylphenidate”:ab,ti OR “Dexmethylphenidate Hydrochloride”:ab,ti OR “Focalin”:ab,ti OR “Dextroamphetamine”:ab,ti OR “Dexedrine”:ab,ti OR “Dextrostat”:ab,ti OR “ProCentra”:ab,ti OR “Zenzedi”:ab,ti OR “mixed amphetamine salts”:ab,ti OR “Adderall”:ab,ti OR “lisdexamfetamine”:ab,ti OR “lisdexamfetamine dimesylate”:ab,ti OR “Vyvanse”:ab,ti OR “Venvanse”:ab,ti OR “Elvanse”:ab,ti OR “Tyvense”:ab,ti OR “Dyanavel”:ab,ti OR “Evekeo”:ab,ti OR “Guanfacine”:ab,ti OR “Sympatholytics”:ab,ti OR “Central alpha-2 Adrenergic Agonist”:ab,ti OR “Clonidine”:ab,ti OR “Intuniv”:ab,ti OR “Estulic”:ab,ti OR “Tenex”:ab,ti OR “Catapres”:ab,ti OR “Clophelin”:ab,ti OR “Kapvay”:ab,ti OR “Nexiclon”:ab,ti OR “Duraclon”:ab,ti OR “Norepinephrine Reuptake Inhibitors”:ab,ti OR “Selective Norepinephrine Reuptake Inhibitors”:ab,ti OR “Adrenergic Uptake Inhibitors”:ab,ti OR “atomoxetine”:ab,ti OR “Strattera”:ab,ti OR “Tricyclic antidepressants”:ab,ti OR “Desipramine”:ab,ti OR “Norpramin”:ab,ti OR “Nortriptyline”:ab,ti OR “Pamelor”:ab,ti OR “Dopamine Reuptake Inhibitors”:ab,ti OR “modafinil”:ab,ti OR “Provigil”:ab,ti OR “Armodafinil”:ab,ti OR “Norepinephrine-dopamine Reuptake Inhibitors”:ab,ti OR “Bupropion”:ab,ti OR “Wellbutrin”:ab,ti OR “Forfivo”:ab,ti OR “Cymbalta”:ab,ti OR “venlafaxine”:ab,ti OR “reboxetine”:ab,ti OR “Monoamine Oxidase Type B inhibitors”:ab,ti OR “Selegiline”:ab,ti OR “Eldepryl”:ab,ti OR “Zelapar”:ab,ti OR “NMDA receptors”:ab,ti OR “N-Methyl-D-aspartate receptor Antagonists”:ab,ti OR “Amantadine”:ab,ti OR “Memantine”:ab,ti OR “Pertofrane”:ab,ti OR “Nuvigil”:ab,ti OR “Cymbalta”:ab,ti OR “duloxetine”:ab,ti OR “Effexor”:ab,ti OR “Eldepryl”:ab,ti OR “Emsam”:ab,ti OR “Trevilor”:ab,ti OR “Symmetrel”:ab,ti OR “Namenda”:ab,ti OR “Zelapar”:ab,ti
#9 | #7 OR #8
#10 | [mh “Attention Deficit Disorder with Hyperactivity”/DH] OR [mh “Attention Deficit Disorder with Hyperactivity”/RH] OR [mh Psychotherapy] OR [mh “Behavior Therapy”] OR [mh “Parent-Child Relations”] OR [mh “Play Therapy”] OR [mh “Cognitive Therapy”] OR [mh “Time Management”] OR [mh “Computer-Assisted Instruction”] OR [mh “Diet Therapy”] OR [mh “Omega-3 Fatty Acids”/TU] OR [mh Vitamins/AD] OR [mh Vitamins/TU] OR [mh “Food Additives”/AE] OR [mh Probiotics/TU] OR [mh “Acupuncture Therapy”] OR [mh “Remedial Teaching”] OR [mh “Early Intervention (Education)”] OR [mh “Complementary Therapies”] OR [mh “Combined Modality Therapy”]
#11 | “psychosocial therapy”:ab,ti OR “psychosocial intervention”:ab,ti OR “psychosocial interventions”:ab,ti OR “psychosocial approach”:ab,ti OR “psychosocial approaches”:ab,ti OR “psychosocial treatment”:ab,ti OR “psychosocial support”:ab,ti OR “psychoeducation”:ab,ti OR “nonpharmacologic therapy”:ab,ti OR “nondrug therapy”:ab,ti OR “non-drug therapy”:ab,ti OR “Play Therapy”:ab,ti OR “cognitive behavioral therapy”:ab,ti OR “cognitive behavior therapy”:ab,ti OR “cognitive behavioural therapy”:ab,ti OR “cognitive behaviour therapy”:ab,ti OR Mindfulness:ab,ti OR complementary:ab,ti OR “alternative medicine”:ab,ti OR “alternative therapy”:ab,ti OR “alternative therapies”:ab,ti OR “Interpersonal skills training”:ab,ti OR “Parent-Child Interaction Therapy”:ab,ti OR “parent training”:ab,ti OR “parent engagement”:ab,ti OR “parent management”:ab,ti OR “parenting skills”:ab,ti OR “parenting intervention”:ab,ti OR “parenting interventions”:ab,ti OR “Barkley’s defiant child”:ab,ti OR “Teacher-Child Interaction Training”:ab,ti OR “Incredible Years”:ab,ti OR “New Forest Parenting”:ab,ti OR “Triple P”:ab,ti OR “Helping the Noncompliant Child”:ab,ti OR “child life and attention skills”:ab,ti OR “clas”:ab,ti OR PCIT:ab,ti OR “parent child interaction therapy”:ab,ti OR “Summer Treatment Program”:ab,ti OR “Daily Report Card”:ab,ti OR “organization skills”:ab,ti OR “organizational skills”:ab,ti OR “time management”:ab,ti OR “homework intervention”:ab,ti OR braintrain:ab,ti OR “memory training”:ab,ti OR “Captain’s log mindpower builder”:ab,ti OR “memory gyms”:ab,ti OR “attention gym”:ab,ti OR “smartdriver plus”:ab,ti OR “smartmind pro”:ab,ti OR “RoboMemo”:ab,ti OR “play attention”:ab,ti OR metronome:ab,ti OR brainmaster:ab,ti OR mindmed:ab,ti OR “attention lab”:ab,ti OR (activate:ab,ti AND c8:ab,ti) OR “attention training”:ab,ti OR “CogniPlus”:ab,ti OR cogmed:ab,ti OR “working memory training”:ab,ti OR biofeedback:ab,ti OR neurofeedback:ab,ti OR neuroagility:ab,ti OR neuroptimal:ab,ti OR acupuncture:ab,ti OR “vision training”:ab,ti OR “visual training”:ab,ti OR “vision therapy”:ab,ti OR “education intervention”:ab,ti OR “cognitive remediation”:ab,ti OR neurotherapy:ab,ti OR “elimination diet”:ab,ti OR “diet therapy”:ab,ti OR ((“low carb” OR “low carbohydrate” OR “low carbohydrates”:ab,ti OR “gluten free”) AND diet:ab,ti) OR “feingold diet”:ab,ti OR “red dye”:ab,ti OR ((vitamin:ab,ti OR vitamins:ab,ti) AND (supplement:ab,ti OR supplements:ab,ti)) OR “herbal supplement”:ab,ti OR “herbal supplements”:ab,ti OR probiotics:ab,ti OR “omega 3”:ab,ti OR “slow cortical potentials”:ab,ti OR “few foods diet”:ab,ti OR “oligoantigenic diet”:ab,ti OR “restriction diet”:ab,ti OR “food intolerance”:ab,ti OR “food allergy”:ab,ti OR “food allergies”:ab,ti OR “food sensitivity”:ab,ti OR “food sensitivities”:ab,ti OR “multimodal treatment”:ab,ti OR homeopathy:ab,ti OR homeopathic:ab,ti OR chiropractic:ab,ti OR chiropractor:ab,ti
#12 | #10 OR #11
#13 | #12 OR #9
#14 | #3 AND #6 AND #13
#15 | #14, since 2009, limited to CDSR

### Key Question 3

Set # | Terms
#1 | [mh “Attention Deficit Disorder with Hyperactivity”]
#2 | “attention deficit hyperactivity disorder”:ab,ti OR “ADHD”:ab,ti OR “attention deficit disorder”:ab,ti
#3 | #1 OR #2
#4 | [mh Pediatrics] OR [mh Adolescent] OR [mh Infant] OR [mh Child]
#5 | child:ab,ti OR children:ab,ti OR infant:ab,ti OR infants:ab,ti OR preschool:ab,ti OR preschooler:ab,ti OR pediatric:ab,ti OR teenager:ab,ti OR teenagers:ab,ti OR teenaged:ab,ti OR teen:ab,ti OR teens:ab,ti OR adolescent:ab,ti OR adolescents:ab,ti OR adolescence:ab,ti OR youth:ab,ti
#6 | #4 OR #5
#7 | [mh “Secondary Care”] OR [mh “Comprehensive Health Care”]
#8 | “primary care”:ab,ti OR monitor:ab,ti OR monitored:ab,ti OR monitoring:ab,ti OR “follow up”:ab,ti OR “followed up”:ab,ti OR visit:ab,ti OR visits:ab,ti OR session:ab,ti OR sessions:ab,ti OR appointment:ab,ti OR appointments:ab,ti
#9 | #7 OR #8
#10 | #3 AND #6 AND #9
#11 | #10, since 2009, limit to CDSR

## Gray Literature Searches

### ClinicalTrials.gov (November 28, 2016)

Category | Description
Conditions | ADHD OR attention deficit
Recruitment | Completed studies
Study Results | All studies
Study type | Interventional studies
Age group | Child
Phase | Phase 2, Phase 3, Phase 4

Total number of results for screening: 377

### WHO: International Clinical Trials Registry Platform Search Portal (November 28, 2016)

Category | Description
Conditions | ADHD OR attention deficit
Recruiting status | All

Total number of results exported: 945 records/828 trials

Results were imported into an excel file and refined as follows:

1. Removed records with a registration date of December 31, 2004 or earlier; records with an enrollment start date of December 31, 2004 or earlier; records of recruiting studies; records with a population age above 17 years; studies that were explicitly designated as Phase 0 or 1—497 records.
2. Removal of records originating from ClinicalTrials.gov (the ClinicalTrials.gov database was searched separately)—302 records removed, 195 remaining.

Total number of results for screening: 195

### National Guidelines Clearinghouse (November 28, 2016)

Platform: www.guideline.gov

Category | Description
Keywords | ADHD OR “attention deficit disorder” OR “attention deficit hyperactivity disorder”
Age of Target Population | Adolescent (13 to 18 years), Child (2 to 12 years), Infant (1 to 23 months), Infant, Newborn (to 1 month)
Publication Year | 2009, 2010, 2011, 2012, 2013, 2014, 2015

Total number of results: 37