# Acronyms and Abbreviations

Acronym/Abbreviation: Definition
AAP: American Academy of Pediatrics
AACAP: American Academy of Child and Adolescent Psychiatry
ACES: Adverse Childhood Experiences Study
ADHD: Attention deficit hyperactivity disorder
ADHD-C: Attention deficit hyperactivity disorder-combined type
ADHD-HI: Attention deficit hyperactivity disorder-hyperactive/impulsive type
ADHD-I: Attention deficit hyperactivity disorder-inattentive type
ADHD-RS: Attention Deficit Hyperactivity Disorder Rating Scale
ADHD RS-IV: Attention Deficit Hyperactivity Disorder Rating Scale 4
AHRQ: Agency for Healthcare Research and Quality
ATTEX: Attention and Executive Function Rating Inventory
ATX: Atomoxetine
AUC: Area under the curve
AV: Atrioventricular
BASC-2: Behavior Assessment System for Children, Second Edition
BASC-2 BESS: Behavior Assessment System for Children, Second Edition Behavioral and Emotional Screening System
BPT: Behavioral parent training
BRIEF: Behavior Rating Inventory of Executive Function
CANTAB: Cambridge Neuropsychological Test Automated Battery
CARE: Coping With ADHD Through Relationships and Education
CBCL: Child Behavior Checklist
CBRS: Comprehensive Behavior Rating Scale
CBT: Cognitive behavioral therapy
CBV: Caudate body volume
CD: Conduct disorder
CDI: Children’s Depression Inventory
CDSR: Cochrane Database of Systematic Reviews
CER: Comparative effectiveness review
CGI: Conners’ Global Index; Clinical Global Impression
CGI-S: Clinical Global Impression Severity
CGI-SS: Clinical Global Impression of Severity of Suicidality
CHEXI: Childhood Executive Functioning Inventory
CHIP-CE-PRF: Child and Health Illness Profile Child Edition, Parent Report Form
CHP-AS: Challenging Horizons Program After School
CHP-M: Challenging Horizons Program Mentoring
CI: Confidence interval
CDI: Children’s Depression Inventory
CLAS: Child Life and Attention Skills
Cog-Fun: Cognitive Functional intervention
Cogmed: Computerized memory training program
Conners 3: Conners 3rd Edition
Conners CPT: Conners Continuous Performance Test
CPFT: Continuous Performance Function Test
CPRS: Conners Parent Rating Scale
CPT: Continuous Performance Test
CRS: Conners Rating Scale
CRS-P: Conners Rating Scale Parent
CRS-T: Conners Rating Scale Teacher
CTRS: Conners Teacher Rating Scale
DASS: Depression Anxiety Stress Scale
DB-DOS: Disruptive Behavior Diagnostic Observation Schedule
DBDRS: Disruptive Behavior Disorder Rating Scale
DBRS: Disruptive Behavior Rating Scale
DBP: Diastolic blood pressure
DEX: Dextroamphetamine
DHA: Docosahexaenoiacid
DICA-IV: Diagnostic Interview for Children and Adolescents 4
DISC-IV: Diagnostic Interview Schedule for Children Version IV
DSM-5: Diagnostic and Statistical Manual of Mental Disorders, 5^th^ Edition
DSM-IV-TR: Diagnostic and Statistical Manual of Mental Disorders, 4^th^ Edition, Text Revision
D-TMP: Dexmethylphenidate
ECG: Electrocardiograph
ED: Emergency department
EEG: Electroencephalograph, electroencephalogram, electroencephalography
EHC: Effective Health Care
EIS: Electro-interstitial scan
EMBASE: Excerpta Medica Database
EPA: Eicosapentaenoic acid
EPC: Evidence-based Practice Center
ERP: Event-related potentials
ES: Effect size
FDA: Food and Drug Administration
FSSEE: Family-School Success–Early Elementary
GIR: Guanfacine immediate release
GPA: Grade point average
GXR: Guanfacine extended release
HR: Hazard ratio
ICD-10: 10^th^ revision of the International Statistical Classification of Diseases and Related Health Problems
ICTRP: International Clinical Trials Registry Platform
IRS: Impairment Rating Scale
IVA-2 (BrainTrain, Inc): Integrated Visual and Auditory 2
IVA-AE2 (BrainTrain, Inc): Integrated Visual and Auditory Advanced Edition 2
IVA-CPT: Integrated Visual and Auditory Continuous Performance Test
IVA-QS (BrainTrain, Inc): Integrated Visual and Auditory Quick Screening
K-DBDS: Kiddie Disruptive Behavior Disorder Schedule
K-DISC-IV: Kiddie Computerized Diagnostic Interview Schedule for Children
KQ: Key Question
K-SADS-PL: Kiddie Schedule for Affective Disorders and Schizophrenia Present and Lifetime Version
LA: Linoleic acid
LDX: Lisdexamfetamine
MAS: Mixed amphetamine salts
MASC: Multidimensional Anxiety Scale for Children
MATH-CPT: Mathematics Continuous Performance Test
MEDLINE: National Library of Medicine bibliographic database
Mini KID: Mini International Neuropsychiatric Interview for Children and Adolescents
MPH: Methylphenidate
MRI: Magnetic resonance imaging
MTA: Multisite Multimodal Treatment Study of Children with ADHD
NA: Not applicable
NDG: Ningdong granule
NEBA: Neuropsychiatric EEG-Based Assessment AID
NICHQ Vanderbilt Assessment Scale–PARENT: National Institute for Children’s Health Quality Vanderbilt Assessment Scale Parent
NICHQ Vanderbilt Assessment Scale–TEACHER: National Institute for Children’s Health Quality Vanderbilt Assessment Scale Teacher
NIMH: National Institute of Mental Health
NS: Not significant
NSS: Neurological subtle signs
ODD/CD: Oppositional defiant disorder/Conduct disorder
OROS-MPH: Osmotic release oral system methylphenidate
PACS: Parental account of children’s symptoms
PATS: Preschool ADHD Treatment Study
P-DBDRS: Parent Disruptive Behavior Disorder Rating Scale
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, Settings
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
PROSPERO: Prospective Register of Systematic Reviews
PS: Phosphatidylserine
RBBB: Right bundle branch block
RR: Relative risk
RCT: Randomized controlled trial
ROC: Receiver operator characteristic
SBP: Systolic blood pressure
SD: Standard deviation
SDQ: Strengths and Difficulties Questionnaire
SDSC: Sleep Disturbance Scale for Children
SE: Standard error
SMD: Standardized mean difference
SNAP-IV: Swanson, Nolan and Pelham Revision
SOE: Strength of evidence
STAND: Supporting Teens’ Autonomy Daily
STEPP: Strategies to Enhance Positive Parenting
SWAN: Strengths and Weaknesses of ADHD and Normal Behavior
TBR: Theta/beta ratio
TEP: Technical expert panel
TOVA: Test of Variables of Attention
WHO: World Health Organization
WIAT: Wechsler Individual Achievement Test
WJ: Woodcock-Johnson test of achievement
WRAT: Wide Range Achievement Test
WPREMB: Weekly Parent Ratings of Evening and Morning Behavior
XR: Extended release