# Results

## Introduction

We begin by describing the results of our literature searches. We then provide a brief description of the included studies. We provide a detailed description of the studies, key summary points, a detailed analysis of the results, and a table that presents the strength of evidence (SOE).

## Results of Literature Searches

The literature searches identified three randomized controlled trials (RCTs) and 12 additional studies (see Figure 2). Articles that were excluded at the full-text level with reasons for their exclusion are listed in Appendix B.

Figure 2 Literature flow diagram

KQ=Key Question; RCT=randomized controlled trial

Figure 2 shows a study flow diagram. The number of citations identified by the literature searches (651) enters the flow diagram at the top. These citations are screened by title, with the number excluded (333) listed in a box to the right. Abstract screening then occurs, and the citations excluded during abstract screening (244) exit the flow diagram to the right. Continuing down the flow diagram, the number of articles retrieved (74) for full-article screening are shown in a box, and then they are screened a first time by methodologists, against a core set of inclusion criteria. Excluded articles (48) exit the diagram to the right. Continuing down the flow diagram, the remaining articles (26) are screened a second time, by clinical experts as well as methodologists, against the full set of inclusion criteria. Excluded articles (11) exit the diagram to the right and are listed in a large box with specific reasons for exclusion. Finally, at the bottom of the flow diagram the number and design of included studies (15 articles) is shown.

## Key Question 1 What are the benefits and harms of using bronchial thermoplasty in addition to standard treatment for the treatment of adult (≥18 years) patients with asthma?

### Description of Included Studies

Fifteen studies were included to address the benefits and harms of bronchial thermoplasty (BT). Six trials, including three RCTs (n=432)^18–20^ and their 5-year, single-arm extension studies,^21–23^ provided outcomes related to safety and efficacy. One of the extension studies also reported data for the control arm through 3 years. Two of the RCTs (Research In Severe Asthma [RISA]^20^ [n=32] and Asthma Intervention Research [AIR]^19^ [n=112]) compared BT plus standard care (i.e., medical management as determined by treating physician) to standard care alone for up to 12 months. The third RCT^18^ (AIR 2, n=288) compared BT (with standard care) with bronchoscopic sham procedures (i.e., bronchoscopy without thermoplasty, along with standard care) as a control for up to 12 months. The manufacturer of the Alair BT system, Boston Scientific, funded all three RCTs. To better assess the generalizability of these studies, we included an additional study comparing outcomes of patients receiving BT as part of an RCT with those of “real-world” patients not enrolled in an RCT who were receiving BT at the same clinic.^24^ For additional consideration of the potential harms of BT, eight descriptive studies were included, consisting of six case studies^25–30^ and two case series.^31,32^

The U.S. Food and Drug Administration (FDA)-approved indication for the Alair system is for severe, persistent asthma in adults whose asthma is not controlled by inhaled corticosteroids (ICS) and long-acting beta agonists (LABA). However, the RCTs included patients with a range of asthma severity. We provide the detailed study inclusion criteria in Table 2.

Table 2 Patient inclusion criteria for the randomized controlled trials of bronchial thermoplasty

Study | Study Inclusion Criteria
RISA Study (Pavord 2007^20^) BT and standard care vs. standard care N=34 | Asthma severity: severe, requiring daily ICS at >750 mcg fluticasone equivalent and LABA 100 mcg salmeterol equivalent; ≤30 mg/d prednisone equivalent; Spirometry: prebronchodilator FEV_1_ ≥50% predicted; airway hyperresponsiveness (methacholine challenge or response to bronchodilator) Additional: Uncontrolled symptoms while on maintenance therapy – rescue medication used on 8 of 14 days prior to enrollment or daytime symptoms on 10 of 14 days; nonsmoker ≥1 year
AIR Study (Cox 2007^19^) BT and standard care vs. standard care N=112 | Asthma severity: moderate or severe, requiring daily ICS at >200 mcg BPD equivalent and LABA 100 mcg salmeterol equivalent; stable disease in 6 weeks prior to entry Spirometry: prebronchodilator FEV_1_ 60 to 85% predicted; Methacholine PC_20_ <8mg/mL Additional: Worsening of ACQ ≥0.5 when off LABA for 2 weeks; <3 lower respiratory tract infections requiring antibiotics in previous 12 months, none in prior 6 weeks; nonsmoker ≥1 year; <4 puffs/day short-acting beta-2 agonist
AIR 2 (Castro 2010^18^) BT and standard care vs. sham (bronchoscopy without thermoplasty) and standard care N=297 | Asthma severity: severe asthma requiring daily ICS at >1,000 mcg BPD equivalent and LABA 100 mcg salmeterol equivalent; <10 mg OCS/day; ≥2 symptomatic days in prior 4 weeks Spirometry: prebronchodilator FEV_1_ ≥60% predicted; Methacholine PC_20_ <8mg/mL Additional: AQLQ ≤6.25;<3 hospitalizations for asthma; <3 lower respiratory tract infections and <4 pulses of OCS in prior year; Additional exclusions: “life threatening” asthma; use of immunosuppressants, beta-adrenergic blocking agents or anticoagulants; chronic sinus disease or emphysema; smoking in past year or ≥ 10 pack-year smoking history

ACQ: Asthma Control Questionnaire (Range 0–6); AIR: Asthma Intervention Research; AQLQ: Asthma Quality of Life Questionnaire (Range 1–7); BT: bronchial thermoplasty; ED: emergency department; FEV_1_: forced expiratory volume in 1 second; ICS: inhaled corticosteroid; LABA: long-acting beta-2 agonist; mcg: microgram; mg/mL: milligrams per milliliter; OCS: oral corticosteroids; PC_20_=provocative concentration of methacholine causing a 20% drop in FEV_1_; RISA: Research In Severe Asthma

The standard care provided during the course of the studies was a continuation of maintenance treatments (e.g., ICS with or without oral corticosteroids, LABA) at entry. Patients in the AIR study received prednisone 50 mg the day of and day after each BT procedure, then maintenance therapy until month 3, at which point the LABA was withdrawn for at least 2 weeks. If symptoms emerged, the LABA was resumed, and additional attempts were made to withdraw it at 6 months and 12 months.^19^ In the RISA study, patients in both groups were given 50 mg of prednisone per day for 5 days starting 3 days before each BT procedure (or comparable clinic visit for controls). Steroid dose was kept stable until 22 weeks (“steroid stable phase”), then attempts were made to reduce the dose of oral corticosteroids and ICS gradually over the remaining 30 weeks (“steroid wean phase,” weeks 22–36; “reduced steroid phase,” weeks 36–52).^20^ The AIR 2 study publications do not describe a specific protocol for changes to maintenance medications during follow up.^18^

The schedule for BT procedures was uniform across studies, i.e., three procedures were performed 3 weeks apart. The 6 weeks after the third BT procedure was also considered a part of the “treatment period” in all of the studies.

Detailed evidence tables presenting information on the design of the studies, study inclusion criteria, study population descriptions, findings, risk-of-bias assessments and detailed strength of evidence assessments are located in Appendix C. A table of minimum important differences in asthma-related outcomes is provided in Appendix D. A table of ongoing clinical trials is presented as Appendix E.

### Key Points

- Patients treated with BT and standard care (medical management) showed statistically greater improvements in asthma control (as measured by the Asthma Control Questionnaire [ACQ]), and quality of life (as measured by the Asthma Quality of Life Questionnaire [AQLQ]) compared with patients undergoing standard care (medical management) only (SOE: low). However, the clinical importance of the changes is unclear.
- Evidence as to whether patients treated with BT and standard care versus standard care alone experienced different rates of severe exacerbations following the treatment period (3 procedures over 6 weeks, followed by an additional 6 weeks) was inconclusive (SOE: insufficient). While rates of mild exacerbations improved to a greater extent in the BT and standard care group than in the standard care only group, the clinical importance of the difference is unclear. (SOE: low).
- Patients treated with BT and standard care used statistically significantly less rescue medication than patients receiving standard care alone, but the clinical importance of the difference is unclear. (SOE: low).
- Patients given BT and standard care had no difference in asthma control scores, as measured by ACQ; in hospitalizations for respiratory symptoms; in use of rescue medication; in number of days rescue medications were required; or in pulmonary physiology measures (forced expiratory volume in 1 second [FEV_1]_ and morning peak expiratory flow [PEF]) compared with patients given the sham bronchoscopic procedure and standard care (SOE for all outcomes: low).
- Patients treated with BT and standard care experienced statistically significantly fewer exacerbations (those requiring systemic corticosteroids or doubling of inhaled corticosteroid dose) compared with those receiving the sham bronchoscopic procedure and standard care after the treatment period (3 procedures over 6 weeks, followed by an additional 6 weeks) was complete through the 12-month followup (post-treatment period), but the clinical importance of this difference was unclear (SOE: low).
- Patients treated with BT and standard care had fewer emergency department (ED) visits compared with those receiving the sham bronchoscopic procedure and standard care during the post-treatment period. (SOE: moderate).
- Evidence as to whether patients receiving BT and standard care versus the sham bronchoscopic procedure and standard care had different quality of life (AQLQ) scores was inconclusive (SOE: insufficient). Analysis of results for the intention-to-treat population found no improvement, but analysis of results for the per-protocol population found a difference that may not be clinically important, as it did not achieve the minimum important difference for this measure. A responder analysis (proportion of patients who achieved the minimum important difference) favored the BT and standard care intervention, but this outcome was not prespecified.
- Patients treated with BT developed the following common adverse events: bronchial irritation, chest discomfort, cough, discolored sputum, dyspnea, night awakenings, and wheezing. Serious adverse events occurred more frequently in BT treated patients than in patients receiving the sham bronchoscopic procedure and/or standard care during the 12-week treatment period. No deaths were attributed to BT.

### Detailed Synthesis

#### Asthma Control

Low-strength evidence from two RCTs (AIR [n=112] and RISA [n=32]) suggests that patients with moderate to severe asthma (AIR) and severe asthma (RISA) treated with BT and standard care have greater improvement in ACQ scores than patients treated with standard care alone. (We calculated the following from data in the publications: AIR: Standardized mean difference [SMD] in ACQ change score:−0.78, 95% Confidence Interval [CI]: −1.17 to −0.39; RISA: SMD in ACQ score change=−0.96, 95% CI: −1.69 to −0.23.)^19,20^ The clinical significance of this finding is uncertain as the upper bounds of the CI is less than the minimum important difference of 0.5 (See Table D-1 in Appendix D). In contrast, low-strength evidence in the AIR 2 trial comparing BT and standard care with a sham bronchoscopic procedure and standard care found no difference in ACQ scores. (We calculated SMD in ACQ change score:−0.05, 95% CI: −0.29 to 0.19).^18^

A small retrospective study (n=25) compared 10 patients presenting at a clinic for BT treatment with 15 patients treated at the same institution who enrolled in RCTs of BT. The study suggests that patients treated with BT while enrolled in an RCT at this site saw statistically greater but not clinically important, improvement in ACQ than those treated with BT outside an RCT (clinic: mean change=−0.5; 95% CI: −1.5 to 0.4; RCT: mean change=−0.8; 95% CI:−1.4 to −0.1, [upper bound below the minimum important difference]).^24^ However, due to limitations related to the study design, lack of precision in the results (small sample size), and unknown consistency, insufficient evidence exists to determine whether differences in patient characteristics explain lower rates of success in the clinic patients. For example, patients not in RCTs who received BT were allowed to be on omalizumab, high-dose oral prednisolone, and were not excluded based on frequency of exacerbations, characteristics that could have made some patients ineligible for the RCTs. They were also on higher doses of ICS and were more likely to be at Step 5 than patients enrolled in RCTs.

#### Exacerbations

In the AIR RCT, investigators derived exacerbation data from daily diaries that recorded any of the following on two consecutive days during a 2-week period of abstinence from LABA at 3, 6, and 12 months:

- Reduction in the morning PEF of at least 20% below the average (based on the value measured in the week prior to withdrawal of LABA at baseline)
- Requiring three or more puffs of rescue medication above their average use (based on the average number of puffs per day prior to withdrawal of LABA at baseline)
- Night awakening due to asthma symptoms.

The evidence from the AIR RCT comparing BT and standard care to standard care alone (n=112) was inconclusive regarding differences in rates of severe exacerbations (those requiring systemic corticosteroids or a reduction in PEF of at least 30% below average) at 12 months.^19^ The study found a statistically significant reduction in mild exacerbations in the BT and standard care group compared to the change in mild exacerbations in the standard care only group (calculated mean difference=−0.20, 95% CI=−0.95 to −0.15 mild exacerbations per patient per week, or approximately 10 fewer mild exacerbations per year, 95% CI=3 to 18 fewer per year) at 12 months. We assessed the SOE as low given the study limitations, unknown consistency, and indirectness of measuring exacerbations only while patients were abstaining from LABA for 2 weeks.

The AIR RCT comparing BT and standard care to standard care alone (n=112) reported no difference in rates of hospitalization for respiratory events (3 hospitalizations in 3 patients in BT and standard care group vs. 3 hospitalizations in 2 patients in the standard care group) during the post-treatment period (up to 12 months after the last treatment).^19^ The single-arm extension study reported that the rate of hospitalizations “did not get worse compared to year 1 after BT (p=0.15; repeated measures analysis for proportion of subjects).”^22^

The RISA RCT comparing BT and standard care to standard care alone (n=32) also found no between-group difference in hospitalizations for respiratory events (BT: 5 hospitalizations vs. standard care: 4 hospitalizations, reported p-value =0.32) during the post-treatment period (6 weeks after the third BT procedure through 52 weeks).^20^ In the single-arm extension of this study, overall respiratory-related hospitalizations decreased in patients treated with BT and standard care over 5 years compared with baseline, but the change was not statistically significant.^23^ Similarly, while the rate of ED visits over 5 years declined compared to the baseline rate, the change was not statistically significant in this small study.^23^

Low-strength evidence from the AIR 2 trial (n=288) found that patients treated with BT and standard care had fewer severe exacerbations (those requiring systemic corticosteroids or doubling of ICS dose) in the post-treatment period (i.e., 6 weeks after the last BT procedure through 12 months) than patients treated with the sham bronchoscopic procedure and standard care. The posterior probability of superiority (PPS) for this result was 95.5 percent, meeting the study’s criterion for statistical significance for this outcome.^18^ However, the FDA statistician noted in his presentation to the Anesthesiology and Respiratory Therapy Devices Panel that the credible interval for the difference crossed 0 (i.e., difference in severe exacerbations per subject per year =0.48 in the BT group versus 0.70 in the sham group, credible interval for the difference of −0.31 to 0.52).^33^ Use of the PPS to determine statistical significance is a less stringent criterion than considering the width of the credible interval. After considering the data presented by FDA, we determined that the findings were imprecise.

In the AIR 2 extension study, the reductions in the proportion of BT-treated patients experiencing severe exacerbations in each of the 5 years compared to the proportion in year 1 were not significantly different, since the upper 95% confidence limits for the differences in proportions were each less than the pre-defined noninferiority margin of 20 percent. However, exacerbations during years 2 to 5 were only ascertained at annual visits and confirmed by medical record review. This method of data collection differed from the use of diaries for recording exacerbations during the original study, and there was no information provided on the completeness or reliability of exacerbation reporting at the annual visits.^21^

The AIR 2 study found no difference in respiratory-related hospitalizations (10.5% vs. 5.1%; PPS for the rate in the sham bronchoscopic procedure group being higher than for the BT group, 57.2%) through 12 months.^18^ Compared with the sham bronchoscopic procedure and standard care, the AIR 2 RCT found that BT and standard care reduced the rate of ED visits for respiratory symptoms by 84 percent, (0.45 visits per subject over 12 months in the sham and standard care group versus 0.13 visits per subject over 12 months in the BT and standard care group; PPS 99.9%, meeting the study’s criterion for statistical significance for this outcome) (moderate SOE).^18^ In the long-term extension of this RCT, ED visits (per subject per year) for respiratory symptoms were reduced in patients treated with BT and standard care by 88 percent over 5 years compared with 12 months before the procedure.^21^ ED visits and hospitalizations were reported by patients only at annual visits during years 2 to 5.

#### Other Measures of Health Care Utilization

Two RCTs suggested that BT and standard care reduced rescue medication use compared with standard care alone at 12 months but the difference did not meet the minimally important difference (MID).^19,20^ Inconclusive evidence from the AIR 2 RCT found no difference between BT with standard care and the sham bronchoscopic procedure with standard care in reducing rescue medication or percentage of days with use of rescue medication at the 12-month followup (PPS: 81.3% and 68.0%).^18^

#### Pulmonary Physiology

The three RCTs with 5-year followup and a retrospective comparative trial reported spirometry data (either FEV_1_ or PEF). When measured prior to administration of a bronchodilator, FEV_1_ improved transiently in the patients treated with BT and standard care in the RISA trial (n=30) compared with standard care alone at 22 weeks from baseline (i.e., during the steroid stable phase; between-group mean difference calculated based on reported data: 15.8%, 95% CI:1.8: 1.8% to 29.8%). However, there was no significant difference between groups in FEV_1_ when measured postbronchodilator or at a later followup once steroids had been weaned and stabilized (i.e., by 52 weeks).^20^ In the RISA extension, postbronchodilator FEV_1_ (% predicted) did not significantly decline in the group receiving BT and standard care over 5 years of followup or in the control group over 3 years of followup.^23^

In the AIR study (n=112), patients treated with BT and standard care had greater increases in morning and evening PEF compared with standard care alone) from baseline to 12 months; differences in FEV_1_ (% predicted, prebronchodilator) were not significant.^19^ This evidence from the AIR and RISA trials was considered inconclusive (SOE: insufficient). Mean FEV_1_ (% predicted, postbronchodilator) remained stable in the control group (i.e. in the 24 of 49 who agreed to long-term followup) over 3 years of followup and in BT-treated patients through the 5-year followup.^22^

In the AIR 2 RCT (n=288) comparing BT and standard care to the sham bronchoscopic procedure and standard care treatment, there was no change in FEV_1_ (% predicted, prebronchodilator) or morning PEF (L/min) between baseline and 12 months (PPS 24.1% and 80.6%, respectively) (SOE: low). No statistically significant change in FEV_1_ occurred in BT-treated patients from the 12-month through the 5-year followup.^18,21^

In the comparison of clinic patients treated with BT to randomized patients treated with BT, FEV_1_ (% predicted, prebronchodilator) change at 12 months was not significantly different.^24^

The AIR RCT found that BT and standard care did not improve airway hyper-responsiveness (defined by a provocative concentration of methacholine required to lower the FEV1 by 20% (PC20) of less than 8 mg per milliliter), compared with standard care alone between baseline and 12 months.^19^ But in the AIR extension study, airway hyper-responsiveness remained relatively stable in patients treated with BT and standard care while it worsened in the control group treated with standard care alone who agreed to followup in years 2 and 3.^22^

#### Asthma-Related Quality of Life

Two studies (AIR and RISA) with low-strength evidence suggested that BT and standard care significantly improved AQLQ scores compared with standard care alone at 12 months from baseline.^19,20^ The mean difference in improvement exceeded the MID in both studies, but the lower bounds of the 95% CI for the estimate from the AIR study did not exceed the MID. Consequently, we consider the result imprecise and the clinical importance uncertain (SOE: low).

The AIR 2 RCT found a statistically greater increase in AQLQ score with BT and standard care compared with the sham bronchoscopic procedure and standard care in the per-protocol population (PPS, 97.9%), but not in the intent-to-treat population (PPS, 96.0% [target PPS for this outcome was 96.4%]). The difference between groups in the change in AQLQ from baseline to the 12-month followup was less than the MID of 0.5 in both intent-to-treat and per-protocol populations (see Table D-1 in Appendix D). The proportion of patients with improvement in AQLQ score greater than the MID was higher after BT and standard care than after the sham bronchoscopic procedure and standard care (PPS, 99.6%). However, this was not a prespecified outcome, raising concern about the possibility of outcome reporting bias.^18^ Given the differences in results from these three different analytic approaches, we assessed the findings as inconclusive and the SOE as insufficient.

In the observational study comparing two populations undergoing BT, no difference was observed in AQLQ between patients treated with BT in the context of a RCT compared with patients treated with BT outside the RCTs.^24^ However, due to limitations related to the observational nature of the study design, lack of precision in the results, and unknown consistency, insufficient evidence exists to determine whether differences in patient populations factor significantly into patient outcomes in RCTs of BT.

#### Asthma Symptoms (Secondary Outcome)

Low-quality evidence from the AIR RCT (n=112) suggests that BT and standard care statistically significantly improved total symptom score from baseline to 12 months compared with standard care alone (between-group mean difference in total symptom score [range 0 to 18] calculated from reported data: −1.20, 95% CI: −2.10 to −0.30.).^19^ We did not identify a minimum important difference for this outcome, but calculating the effect size using Hedges g suggests that this is not an important difference (−0.52, 95% CI −0.91 to −0.12) as the confidence interval is not fully within a margin of 0.2 from 0.

In the AIR 2 study comparing BT and standard care to the sham bronchoscopic procedure and standard care, self-reported symptom scores improved in both groups from baseline. There were no differences between the treatment conditions at 12-month followup (between-group mean difference in total symptom score [range 0 to 18] calculated from reported data: −0.10, 95% CI: −0.66 to 0.46) (SOE: low).^18^

Table 3 presents the findings and SOE ratings for all the comparisons and outcomes assessed.

Table 3 Strength of evidence for bronchial thermoplasty interventions

Comparison | Outcome^a^ | Conclusion | Study Design and Sample Size | Overall Evidence Strength (Limitations^b^)
BT and standard care (medical management) vs. standard care alone | Asthma control | Favors BT, but clinical importance unclear: ACQ scores improved in patients who underwent BT compared to those who received standard medical management, but the upper bounds of the confidence interval was less than the MID. | 2 RCTs^19,20^ n=144 | Low (Medium^c^ study limitations Imprecise; MID not met)
BT and standard care (medical management) vs. standard care alone | Exacerbations Severe | Inconclusive: Rates of severe exacerbations per patient per week did not vary between treatment conditions. Exacerbations were counted during 2-week periods at 3, 6 and 12 months when LABA were discontinued. | 1 RCT^19^ n=112 | Insufficient (Medium^c^ study limitations, indirect [measured while off LABA], unknown consistency, Imprecise)
BT and standard care (medical management) vs. standard care alone | Exacerbations Mild | Favors BT, but clinical importance unclear: Rates of mild exacerbations per patient per week were lower at 3 and 12 months but not at 6 months in patients who received BT and standard care. Exacerbations were counted only during 2-week periods at 3, 6 and 12 months when LABA were discontinued. | 1 RCT^19^ n=112 | Low (Medium^c^ study limitations, indirect [measured while off LABA], unknown consistency)
BT and standard care (medical management) vs. standard care alone | Hospitalizations (after treatment period) | No difference: Rates of hospitalizations were not different in patients who received BT and standard care versus those treated with standard care alone. | 1 RCT n=32 | Low (Medium^c^ study limitations Imprecise)
BT and standard care (medical management) vs. standard care alone | Health care utilization (other than exacerbations) | Favors BT, but clinical importance unclear: Use of rescue medication (puffs per week) was reduced to a greater extent in the BT group than standard care group but does not meet the MID criterion The overall reduction in oral or inhaled corticosteroid dose was not different between treatment groups in 1 small trial.^20^ | 2 RCTs^19,20^ n=144 | Low (Medium^c^ study limitations, Imprecise)
BT and standard care (medical management) vs. standard care alone | Pulmonary physiology: Spirometry | Inconclusive: In 1 small trial, BT and standard care improved FEV_1_ at 22 weeks from baseline; the between-group difference was not significant at 52 weeks.^20^ In the other study, patients treated with BT and standard care had greater increases in morning and evening peak flow compared with standard care alone from baseline to 12 months. Between-group change in FEV_1_ was not significant.^19^ | 2 RCTs^19,20^ n=144 | Insufficient (Medium^c^ study limitations, Inconsistent, Imprecise)
BT and standard care (medical management) vs. standard care alone | Pulmonary physiology: Airway hyper-responsiveness | Inconclusive: Airway hyper-responsiveness did not vary between treatment groups | 1 RCT^19^ n=112 | Insufficient (Medium^c^ study limitations, unknown consistency, imprecise)
BT and standard care (medical management) vs. standard care alone | Quality of life | Favors BT, but clinical importance unclear: AQLQ scores improved in patients who underwent BT and received standard care compared to those who received standard medical management alone. The result from the larger study did not exceed the minimum important difference criterion (lower bounds of the 95% CI was less than 0.5). | 2 RCTs^19,20^ n=144 | Low (Medium^c^ study limitations, Imprecise)
BT and standard care (medical management) vs. standard care alone | Symptoms (Secondary outcome) | Favors BT, but clinical importance unclear: BT and standard care improved total symptom score from baseline to 12 months compared with medical management alone but the difference may not be clinically important. | 1 RCT^19^ n=112 | Low (Medium^c^ study limitations, unknown consistency)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Asthma control | No difference: ACQ scores did not differ at 12 months after either BT and standard care or the sham bronchoscopic procedure and standard care | 1 RCT^18^ n=288 | Low (unknown consistency, imprecise)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Exacerbations: Severe events (after treatment period) | Favors BT, but clinical importance unclear: Patients who underwent BT and standard care had fewer severe exacerbations per patient per year than the sham bronchoscopic procedure and standard care during weeks 12 to 52. Fewer patients experienced severe exacerbations in the BT and standard care group than in the sham group. | 1 RCT^18^ n=288 | Low (Unknown consistency, imprecise [credible interval crosses 0])
BT and standard care vs. the sham bronchoscopic procedure and standard care | Exacerbations: Severe events (during treatment period) | Favors the sham bronchoscopic procedure and standard care: During the treatment period (up to 6 weeks following the 3^rd^ BT or sham treatment), the number of patients experiencing severe exacerbations was higher in the BT group than in the sham group. | 1 RCT^18^ n=288 | Moderate (Unknown consistency)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Exacerbations: ED visits (after treatment period) | Favors BT: Rates of ED visits for respiratory symptoms were lower over 12 months following BT and standard care relative to the sham bronchoscopic procedure and standard care | 1 RCT^18^ n=288 | Moderate (Unknown consistency)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Exacerbations: Hospitalizations (after treatment period) | No difference: Hospitalizations for respiratory symptoms at 12 month followup | 1 RCT^18^ n=288 | Low (Unknown consistency, imprecise)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Exacerbations: Hospitalizations (during treatment period) | No difference: Hospitalizations for respiratory symptoms during the treatment period (up to 6 weeks following the 3^rd^ BT or sham bronchoscopic procedure) were higher in the BT group than the sham group (but the RR crossed 1) | 1 RCT^18^ n=288 | Low (Unknown consistency, imprecise)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Health care utilization: Rescue medication actuations | No difference: Use of rescue medication at 12 month followup | 1 RCT^18^ n=288 | Low (Unknown consistency, imprecise)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Health care utilization: Days rescue medication required | No difference: % days rescue medication used at 12 month followup | 1 RCT^18^ n=288 | Low (Unknown consistency, imprecise)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Pulmonary physiology | No difference: FEV_1_ and morning peak flow in patients treated with BT and standard care compared with the sham bronchoscopic procedure and standard care from baseline to 12 months | 1 RCT^18^ n=288 | Low (Unknown consistency, imprecise)
BT and standard care vs. the sham bronchoscopic procedure and standard care | Quality of life | Inconclusive: Change in AQLQ scores did not differ in [underlined: intent-to-treat patients] 12 months after either BT and standard care or the sham bronchoscopic procedure and standard care AQLQ improved in [underlined: per-protocol] patients treated with BT and standard care compared with the sham bronchoscopic procedure and standard care at 12 months. However the difference did not achieve the minimum important difference. The proportion of patients with improvement in AQLQ score greater than the minimum important difference was higher after BT and standard care than after the sham bronchoscopic procedure and standard care. However, this was not a prespecified outcome. | 1 RCT^18^ intent-to-treat=288 per protocol=268 | Insufficient (Medium study limitations for per protocol analysis, unknown consistency, Imprecise [95% credible interval for continuous measure crosses 0; upper bound is less than MID], selective reporting possible).
BT and standard care vs. the sham bronchoscopic procedure and standard care | Symptoms (Secondary outcome) | No difference: Symptom scores improved over time in both treatment groups but did not differ as a function of treatment condition | 1 RCT^18^ n=288 | Low (Unknown consistency, imprecise)
BT in RCT patients vs. BT in “real world” clinic patients | Asthma control | Inconclusive: Although ACQ scores were significantly better following BT in patients who were enrolled in the RCTs compared to the patients from clinic who underwent BT, this 1 small nonrandomized study is insufficient for drawing a conclusion. The change from baseline in each group was clinically significant. | 1 non-RCT^24^ n=25 | Insufficient (High study limitations,^d^ unknown consistency, Imprecise)
BT in RCT patients vs. BT in “real world” clinic patients | Exacerbations | Inconclusive: Rates of exacerbations were low in both treatment groups and did not vary statistically | 1 non-RCT^24^ n=25 | Insufficient (High study limitations,^d^ unknown consistency, Imprecise)
BT in RCT patients vs. BT in “real world” clinic patients | Health care utilization | Not evaluable: Data on hospitalizations and medication use not reported in a comparable manner for treatment groups | NA | NA
BT in RCT patients vs. BT in “real world” clinic patients | Pulmonary physiology | Inconclusive: FEV_1_ did not differ significantly between groups | 1 non-RCT^24^ n=25 | Insufficient (High study limitations,^d^ unknown consistency, Imprecise)
BT in RCT patients vs. BT in “real world” clinic patients | Quality of life | Inconclusive: AQLQ scores improved to a clinically significant degree in both treatment groups; difference between groups not significantly different, but sample size was small | 1 non-RCT^24^ n=25 | Insufficient (High study limitations,^d^ unknown consistency, Imprecise)
BT in RCT patients vs. BT in “real world” clinic patients | Symptoms (Secondary outcome) | Not evaluable: Not reported | NA | NA

a Outcomes of Asthma control, Exacerbations, Health care utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;33 outcomes of Quality of life and Symptoms as defined by study authors.

b Study limitations derived from Risk of Bias assessments in Appendix C.

c Study limitations: Lack of participant and outcome assessor blinding were the main concerns. Lack of clarity regarding the role of the funding entity was also considered in this domain, but deemed a lesser concern.

d Observational study, retrospective, groups not comparable on baseline characteristics

ACQ: Asthma Control Questionnaire (Range 0–6); AQLQ: Asthma Quality of Life Questionnaire (Range 1–7); BT: bronchial thermoplasty; CI: confidence interval; ED: emergency department; FEV_1_: forced expiratory volume in 1 second; ; LABA: long-acting beta-2 agonist; MID: minimallym important difference; NA: not available; PEF: peak expiratory flow; PPS: posterior probability of superiority; RCT: randomized controlled trial; RR: relative risk

#### Adverse Events and Mortality

Two RCTs (RISA and AIR) that compared BT to standard care reported that the most common adverse events in patients treated with BT up to six weeks following the third BT procedure (treatment period) were bronchial irritation, chest discomfort, cough, discolored sputum, dyspnea, night awakenings, and wheezing.^19,20^ In both studies, respiratory adverse events were higher in the BT group during the treatment period, but rates did not differ between BT and standard care groups in either study during the post-treatment period through 12-month followup. The RISA RCT (n=32) found that during the 12-week treatment period (i.e., 6 weeks during which 3 BT procedures were performed 3 weeks apart, followed by an additional 6 weeks), 4 of 15 patients treated with BT experienced 7 hospitalizations due to respiratory adverse events compared with no hospitalizations in 17 patients treated with standard care alone.^20^ In the AIR RCT, 4 of 52 patients undergoing BT required 6 hospitalizations during the 12-week treatment period compared to 2 of 48 patients requiring 1 hospitalization each in the standard care control group.^19^

During the AIR extension study, patients from the BT group (n=45) and control group (n=24) were followed for 3 years. During years 2 and 3, there were no significant differences between BT (1.1 to 1.3 events/subject/year) and control group rates (1.2 and 1.3 events/subject/year) of respiratory related events, ascertained at annual visits.^22^

At year 5 of the RISA extension, adverse event rates in patients treated with BT were chest discomfort (8.3%), cough (0%), discolored sputum (0%), and wheezing (8.3%).^23^ The control group was not included in the 5-year followup. At year 5 of the AIR extension, rates of these common adverse events were bronchial irritation (2.4%), chest discomfort (4.8%), cough (4.8%), discolored sputum (0%), dyspnea (9.5%), productive cough (2.4%), night awakenings (0%), and wheezing (4.8%). The control group was not included in the 5-year followup.^19,20^

We supplemented the information on the comparison of adverse events in the AIR 2 trial comparing BT and standard care to a sham bronchoscopic procedure and standard care reported in the journal publication^18^ with data from the FDA presentation to the Anesthesiology and Respiratory Therapy Devices Panel on October 28, 2009.^33^ During the 12-week treatment period, there were 0.20 respiratory adverse events per patient per week in the BT group versus 0.14 in the sham group (169/190 [84%] of patients in the BT group vs. 74/98 [76%] in the sham group experienced a respiratory adverse event). Of these, serious respiratory adverse events constituted 0.007 events per patient per week in the BT group versus 0.002 in the sham group (15/190 [8%] of patients in the BT group vs. 2/98 [2%] in the sham group). The adverse events occurring more frequently during the treatment period in those treated with BT versus those undergoing the. sham bronchoscopic procedure were asthma (defined as multiple symptoms; 52% vs. 39%), upper-respiratory-tract infections (20% vs. 11%), wheezing (15% vs. 6%), dyspnea (11% vs. 6%), lower respiratory tract infection (8% vs. 2%), anxiety (4% vs. 0%), atelectasis (4% vs. 0%), and hemoptysis (3% vs. 0%).^18,33^ Among the six patients who experienced hemoptysis, five had mild to moderate hemoptysis that was self-limiting; however, one patient had severe hemoptysis (defined as >100cc) at 31 days following the procedure, and required intervention.^33^

During the treatment period (up to six weeks after last BT or sham bronchoscopic procedure) in the AIR 2 study, 16 of 190 patients in the BT group required 19 hospitalizations for respiratory adverse events versus only 2 of 98 patients in the sham group. The BT-treated patients requiring hospitalization included ten patients hospitalized for worsening of asthma symptoms, two patients for segmental atelectasis, one for lower respiratory tract infection, one for low FEV_1_, one for aspirated prosthetic tooth, and one for hemoptysis. In the sham-treated subjects, the two hospitalizations during the treatment period were for worsening of asthma.^18^ The investigators state that all adverse events were treated with “standard therapy” (including bronchial artery embolization for hemoptysis). In the 5-year extension that followed the BT arm of the study, respiratory adverse events and asthma symptoms were reduced compared to the first year. Respiratory adverse events occurring at an incidence rate of ≥3% of patients in any of the years 1 through 5 were similar to those listed in the RISA and AIR RCTs above, and included influenza, nasopharyngitis, pneumonia, rhinitis, and sinusitis. There were no cases of pneumothorax, mechanical ventilation, cardiac arrhythmias, or death attributed to BT in the AIR 2 trial.^21^

The nonserious adverse events (e.g., cough, throat irritation, headache, hoarseness) reported in descriptive studies were consistent with those reported in RCTs, although no event rates can be determined from these reports. The serious adverse events reported in the 30 patients described in five case reports and two small case series (including one published in 2006) included five cases of hemoptysis, four cases of atelectasis (often described as due to mucus plugging and requiring hospitalization), two cases of lower respiratory tract infection requiring hospitalization, and one case of lung abscess in the treated lung segment requiring prolonged antibiotic therapy. Additionally, one patient with atelectasis also experienced acute respiratory failure on two occasions, with severe bronchospasm and tachypnea. One patient developed a pulmonary embolism with pleural effusion and bilateral lower-extremity deep venous thrombi following BT. During anticoagulation, she developed a mediastinal hematoma and bloody pleural effusion and was found to have hemorrhaged from a pseudoaneurysm of the bronchial artery thought possibly due to thermal injury from BT. Further details are provided in Appendix Table C-5.

Finally, no deaths were attributed to BT in any of the 15 studies.