# References

1 National Heart, Lung, and Blood Institute. Expert panel report 3: guidelines for the diagnosis and management of asthma. [internet]. Bethesda (MD): National Institutes of Health (NIH); 2007 Jan 01 [accessed 2013 Jun 01]. Available: http://www.nhlbi.nih.gov/guidelines/asthma/.
2 Most recent asthma data. [internet]. Atlanta (GA): Centers for Disease Control and Prevention (CDC); [accessed 2016 Jul 05]. Available: http:www.cdc.gov/asthma/most_recent_data.htm.
3 Trends in asthma morbidity and mortality. Chicago (IL): American Lung Association; 2012 Sep. 26 p. Also available: http://www.lung.org/assets/documents/research/asthma-trend-report.pdf.
4 The global asthma report 2014. Aukland, New Zealand: Global Asthma Network; 2014. 92 p. Also available: http://www.globalasthmareport.org/resources/Global_Asthma_Report_2014.pdf.
5 Asthma national health statistics. [internet]. Atlanta (GA): Centers for Disease Control and Prevention (CDC); [accessed 2016 Apr 01]. Available: http://www.cdc.gov/nchs/fastats/asthma.htm.
6 ECRI Institute. Bronchial thermoplasty (Alair System) for treating adult patients with severe symptomatic asthma. Plymouth Meeting (PA): ECRI Institute; 2014 Oct. 34 p. (Emerging Technology Evidence Report).
7 Draft needs assessment report for potential update of the Expert Panel Report-3 (2007): guidelines for the diagnosis and management of asthma. Bethesda (MD): National Heart, Lung, and Blood Institute (NHLBI); 2015 Jan. 14 p. Also available: https://www.nhlbi.nih.gov/sites/www.nhlbi.nih.gov/files/NHLBAC_Asthma-WG-Report-2015[1].pdf.
8 The effectiveness of indoor allergen reduction and the role of bronchialthermoplasty in the management of asthma. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2016 Oct 4. 18 p. (Evidence-based Practice Center Systematic Review Protocol; Also available: https://effectivehealthcare.ahrq.gov/ehc/products/643/2318/asthma-nonpharmacologic-treatment-protocol-161004.pdf.
9 Leas B, D’Anci K, Apter A, . The effectiveness of indoor allergen reduction and the role of bronchial thermoplasty in the management of asthma. PROSPERO 2017:CRD42017055547 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42017055547.
10 Chalmers I, Adams M, Dickersin K, . A cohort study of summary reports of controlled trials. JAMA. 1990 Mar 9;263(10):1401–5. PMID: 2304219.2304219
11 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. 1987 Mar;8(2):198–203. PMID: 38184063818406
12 Dundar Y, Dodd S, Williamson P, . Case study of the comparison of data from conference abstracts and full-text articles in health technology assessment of rapidly evolving technologies: does it make a difference? Int J Technol Assess Health Care. 2006 Jul;22(3):288–94.16984055
13 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. 1992 Mar;3(3):187–91. PMID: 15866151586615
14 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. In: Cochrane Library [Cochrane methodology review]. Issue 2. Oxford: Update Software; 2001 [accessed 2001 Apr 23]. [35 p]. Available: http://www.cochrane.org/index.htm.
15 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. 1993 Jul;40(7):632–4. PMID: 84031378403137
16 Marx WF, Cloft HJ, Do HM, . The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. AJNR Am J Neuroradiol. 1999 Jun–Jul;20(6):1173–7. PMID: 10445467.10445467
17 Cochrane handbook for systematic reviews of interventions. Version 5.1.0. [database online]. Hoboken (NJ): John Wiley & Sons, Ltd.; 2011 Mar 20 [accessed 2012 Dec 04]. [various p.]. Available: http://handbook.cochrane.org/.
18 Castro M, Rubin AS, Laviolette M, . Effectiveness and safety of bronchial thermoplasty in the treatment of severe asthma: a multicenter, randomized, double-blind, sham-controlled clinical trial. Am J Respir Crit Care Med. 2010 Jan 15;181(2):116–24. Also available: http://dx.doi.org/10.1164/rccm.200903-0354OC. PMID: 19815809.19815809
19 Cox G, Thomson NC, Rubin AS, . Asthma control during the year after bronchial thermoplasty. New Eng J Med. 2007 Mar 29;356(13):1327–7. Also available: http://dx.doi.org/10.1056/NEJMoa064707. PMID: 17392302.17392302
20 Pavord ID, Cox G, Thomson NC, . Safety and efficacy of bronchial thermoplasty in symptomatic, severe asthma. Am J Respir Crit Care Med. 2007 Dec 15;176(12):1185–91. Also available: http://dx.doi.org/10.1164/rccm.200704-571OC. PMID: 17901415.17901415
21 Wechsler ME, Laviolette M, Rubin AS, . Bronchial thermoplasty: long-term safety and effectiveness in patients with severe persistent asthma. J Allergy Clin Immunol. 2013 Dec;132(6):1295–302. Epub 2013 Aug 30. PMID: 23998657.23998657
22 Thomson NC, Rubin AS, Niven RM, . Long-term (5 year) safety of bronchial thermoplasty: asthma intervention research (AIR) trial. BMC Pulm Med. 2011 Feb 11;11:8. Also available: http://dx.doi.org/10.1186/1471-2466-11-8. PMID: 21314924.21314924
23 Pavord ID, Thomson NC, Niven RM, . Safety of bronchial thermoplasty in patients with severe refractory asthma. Ann Allergy Asthma Immunol. 2013 Nov;111(5):402–7. Also available: http://dx.doi.org/10.1016/j.anai.2013.05.002. PMID: 24125149.24125149
24 Bicknell S, Chaudhuri R, Lee N, . Effectiveness of bronchial thermoplasty in severe asthma in ‘real life’ patients compared with those recruited to clinical trials in the same centre. Ther Adv Respir Dis. 2015 Dec;9(6):267–71. Epub 2015 Aug 24. Also available: http://dx.doi.org/10.1177/1753465815601332. PMID: 26307767.26307767
25 McCambridge J, Kruklitis R. Transient bronchial wall thickening after bronchial thermoplasty for asthma. J Bronchology Interv Pulmonol. 2016 Jan;23(1):51–3. Also available: http://dx.doi.org/10.1097/LBR.0000000000000240. PMID: 26705012.26705012
26 Nguyen DV, Murin S. Bronchial artery pseudoaneurysm with major hemorrhage after bronchial thermoplasty. Chest. 2016 Apr;149(4):e95–7. Also available: http://dx.doi.org/10.1016/j.chest.2015.09.016. PMID: 27055718.27055718
27 Balu A, Ryan D, Niven R. Lung abscess as a complication of bronchial thermoplasty. J Asthma. 2015 Aug 9;52(7):740–2. Also available: http://dx.doi.org/10.3109/02770903.2015.1005844. PMID: 25766745.25766745
28 Facciolongo N, Menzella F, Lusuardi M, . Recurrent lung atelectasis from fibrin plugs as a very early complication of bronchial thermoplasty: a case report. Multidiscip Respir Med. 2015;10(1):9. Also available: http://dx.doi.org/10.1186/s40248-015-0002-7. PMID: 25852934.25852934
29 Doeing DC, Husain AN, Naureckas ET, . Bronchial thermoplasty failure in severe persistent asthma: a case report. J Asthma. 2013 Sep;50(7):799–801. Also available: http://dx.doi.org/10.3109/02770903.2013.796974. PMID: 23651158.23651158
30 Mahajan AK, Hogarth DK. Bronchial thermoplasty: therapeutic success in severe asthma associated with persistent airflow obstruction. J Asthma. 2012 Jun;49(5):527–9. Also available: http://dx.doi.org/10.3109/02770903.2012.676124. PMID: 22515527.22515527
31 Doeing DC, Mahajan AK, White SR, . Safety and feasibility of bronchial thermoplasty in asthma patients with very severe fixed airflow obstruction: a case series. J Asthma. 2013 Mar;50(2):215–8. Also available: http://dx.doi.org/10.3109/02770903.2012.751997. PMID: 23252954.23252954
32 Cox G, Miller JD, McWilliams A, . Bronchial thermoplasty for asthma. Am J Respir Crit Care Med. 2006 May;173(9):965–9. Also available: http://dx.doi.org/10.1164/rccm.200507-1162OC. PMID: 16456145.16456145
33 Anesthesiology and Respiratory Therapy Devices Panel meeting. Alair® Bronchial Thermoplasty System. Asthmatx, Inc. [P080032]. [slide presentation]. Sliver Spring (MD): U.S Food and Drug Administration (FDA); 2009 Oct 28 [90 p]. Available: https://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/MedicalDevices/MedicalDevicesAdvisoryCommittee/AnesthesiologyandRespiratoryTherapyDevicesPanel/UCM286219.pdfAnesthesiology and Respiratory.
34 Torrego A, Sola I, Munoz AM, . Bronchial thermoplasty for moderate or severe persistent asthma in adults. Cochrane Database Syst Rev. 2014;3(3):CD009910. PMID: 24585221.24585221
35 Wu Q, Xing Y, Zhou X, . Meta-analysis of the efficacy and safety of bronchial thermoplasty in patients with moderate-to-severe persistent asthma. J Int Med Res. 2011;39(1):10–22. PMID: 2167230321672303
36 Zhou JP, Feng Y, Wang Q, . Long-term efficacy and safety of bronchial thermoplasty in patients with moderate-to-severe persistent asthma: a systemic review and meta-analysis. J Asthma. 2016 Jan 2;53(1):94–100. Also available: http://dx.doi.org/10.3109/02770903.2015.1065424.26383773
37 Grant MD, Blue Cross Blue Shield Asssociation. Bronchial thermoplasty for treatment of inadequately controlled severe asthma. Technol Eval Cent Asses Program Exec Summ. 2015 Mar;29(12):1–5. PMID: 2596219025962190
38 Ichinose M, Sugiura H, Nagase H, . Japanese guidelines for adult asthma 2017. Allergol Int. 2017 Apr;66(2):163–89. Epub 2017 Feb 11. Also available: http://dx.doi.org/10.1016/j.alit.2016.12.005. PMID: 28196638.28196638
39 Chung KF, Wenzel SE, Brozek JL, . International ERS/ATS guidelines on definition, evaluation and treatment of severe asthma. Eur Respir J. 2014 Feb 1;43(2):343–73. Also available: http://dx.doi.org/10.1183/09031936.00202013. PMID: 24337046.24337046
40 National Institute for Health and Clinical Excellence (NICE). Bronchial thermoplasty for severe asthma. London (UK): National Institute for Health and Clinical Excellence (NICE); 2012 Jan. 9 p. (Interventional procedure guidance; no. 419). Also available: http://www.nice.org.uk/nicemedia/live/12774/57927/57927.pdf.
41 Du Rand IA, Barber PV, Goldring J, . British Thoracic Society guideline for advanced diagnostic and therapeutic flexible bronchoscopy in adults. Thorax. 2011 Nov;66(Suppl 3):iii1–21. Also available: http://thorax.bmj.com/content/66/Suppl_3/iii1.full.pdf+html. PMID: 21987439.21987439
42 Scottish Intercollegiate Guidelines Network (SIGN), British Thoracic Society. British guideline on the management of asthma. A national clinical guideline. Edinburgh (Scotland): Scottish Intercollegiate Guidelines Network (SIGN); 2014 Oct. 199 p.
43 Global strategy for asthma management and prevention. Vancouver (WA): Global Initiative for Asthma (GINA); 2014. 146 p.