# Methods

## Topic Refinement and Review Protocol

The National Heart, Lung, and Blood Institute (NHLBI) initially nominated this topic, as described in the Introduction. We generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, and settings). A Technical Expert Panel (TEP) was convened for this report. The TEP consisted of nine scientists and clinicians, including individuals with expertise in the clinical management of pediatric and adult asthma, the use of bronchial thermoplasty (BT), and implementation of environmental-control interventions to reduce exposure to allergens in the home. TEP members participated in conference calls and discussions through email to review the scope, analytic framework, KQs, and PICOTS, and provided input on the information and categories included in evidence tables and the analysis. A list of the TEP members is included in the front matter of this report. The final protocol of the review was posted on the Effective Health Care Web site on October 11, 2016. A full version of our protocol for this systematic review is available online (https://effectivehealthcare.ahrq.gov/ehc/products/643/2318/asthma-nonpharmacologic-treatment-protocol-161004.pdf),^8^ and is registered in PROSPERO (http://www.crd.york.ac.uk/PROSPERO) registration number CRD42017055547).^9^

Based on peer review and public feedback on the draft report, we separated the two KQs described in the protocol into two separate reports. The guidance provided by the TEP and the content included in the posted protocol reflect the larger scope of work as initially planned.

## Literature Search Strategy

### Search Strategy

Literature searches were performed by Medical Librarians at the ECRI Institute Evidence-based Practice Center (EPC) Information Center and followed established systematic review protocols. Searches covered the literature published from database inception (dates vary, see Appendix A) through April 20, 2017.

We searched the following databases using controlled vocabulary and text words: Embase^®^ and MEDLINE^®^ (searched together on the EMBASE.com platform), PubMed ^®^ (In Process citations), CINAHL^®^ (Cumulative Index to Nursing and Allied Health Literature), and the Cochrane Library.

We used text words to search gray literature sources and the Web sites of relevant organizations, such as the U.S. Food and Drug Administration Web site, identified by the clinical experts on the project team. A complete list of the resources we searched, as well as search concepts and strategies, are available in Appendix A.

Reference lists from systematic reviews and meta-analyses were reviewed and compared against our retrieved articles. If a systematic review contained references that appeared to meet our inclusion criteria, but had not been captured by our initial search results, the search strategy was refined to include these articles. Supplemental Evidence and Data for Systematic Reviews submitted by interested parties were also reviewed.

Literature screening was performed in duplicate using the database Distiller SR (Evidence Partners, Ottawa, Ontario, Canada). Literature search results were initially screened for relevancy. Relevant abstracts were screened against the inclusion and exclusion criteria in duplicate. Studies that appeared to meet the inclusion criteria were retrieved and screened again in duplicate against the inclusion and exclusion criteria. All disagreements were resolved by consensus discussion between the two original screeners.

### Inclusion and Exclusion Criteria

#### Publication Criteria

Included articles must have been published as full-length, peer-reviewed studies. Abstracts and meeting presentations were not included because they do not include sufficient details about experimental methods to permit an evaluation of study design and conduct; they may also contain only a subset of measured outcomes.^10,11^ Additionally, it is not uncommon for abstracts that are published as part of conference proceedings to have inconsistencies compared with the final study publication or to describe studies that are never published as full articles.^12–16^

When a study with an English-language abstract but published in a foreign language was identified, the abstract was assessed against the full set of inclusion/exclusion criteria. If the study appeared to fit the inclusion criteria, we evaluated whether excluding the study might result in language bias (e.g., if the findings differ from other included studies.) If language bias seemed unlikely, the study was excluded.

### Study Selection

We followed the PICOTS (Table 1) framework to develop the inclusion criteria for studies. We included studies of adults with a diagnosis of asthma who underwent BT. Studies had to report on the outcomes prespecified in our PICOTS. Study inclusion was not restricted by language of publication or treatment duration. Randomized controlled trials (RCTs) and nonrandomized interventional studies with concurrent controls (e.g., nonrandomized trials) were considered for inclusion for assessment of benefits. Single-arm extensions of RCTs were included to describe long-term changes in efficacy or safety in patients treated with BT. Case reports or case series that describe adverse events were also considered for inclusion for reporting adverse events. In vivo, in vitro, and animal studies were excluded.

Table 1 PICOTS (populations, interventions, comparisons, outcomes, timing, and setting) criteria for including studies in the review

PICOTS | Criteria
Populations | - Asthma; - ≥18 years old
Interventions | - Bronchial thermoplasty
Comparators | Treatments used in patients with asthma excluding thermoplasty; - Standard care: medical management as determined by treating physician; - Sham: bronchoscopy without thermoplasty
Outcomes | Primary Outcomes; - Asthma control; ○ Asthma Control Test™ (ACT™)/Childhood ACT; ○ Asthma Control Questionnaire (ACQ); - Exacerbations; ○ Systemic corticosteroids for asthma for at least 3 days; ○ Asthma-specific hospitalizations; ○ Asthma-specific emergency department visits; ○ Asthma-specific urgent care visits (other than emergency department); ○ Asthma-specific admissions to intensive care unit, or intubations; - Health care utilization and costs; ○ Asthma-specific ambulatory care visits; ○ Asthma-specific medication use (including medication name, dose, duration); ○ Asthma-specific hospitalizations, emergency department visits, urgent care visits; ○ Resource use related to the intervention; - Pulmonary physiology; ○ Peak expiratory flow; ○ Spirometry; ○ Airway hyper-responsiveness; - Quality of life; ○ Asthma Quality of Life Questionnaire; - Death, asthma-specific and all cause; Adverse events; - Patient-reported airway irritation (cough, wheezing, dyspnea, chest discomfort); - Airway compromise; - Upper or lower respiratory tract infections; - Lung collapse; - Hemoptysis
Timing | - Studies with all lengths of followup duration will be considered
Setting | - Clinical settings

### Data Extraction

Data were extracted using Microsoft Word. All extracted data were double-checked by a second investigator. All discrepancies were resolved by consensus discussion among the two investigators and an additional person as needed. Elements abstracted included general study characteristics, patient characteristics, details of interventions, outcomes data, and risk of bias items.

## Risk of Bias Assessment of Individual Studies

We used the Cochrane Collaboration’s tool for assessing risk of bias in RCTs.^17^ Study characteristics were rated as introducing “low,” “high,” or “unclear” risk of bias. Two independent reviewers assessed risk of bias, and discrepancies were addressed through consensus discussion.

We considered the funding source of individual studies as presenting a potentially important risk of bias. Therefore, we noted in the risk of bias table any study that reported receiving all or part of its funding from a commercial manufacturer of an intervention or was coauthored by one or more of its employees. We rated the “Other Sources of Bias” component in the Cochrane scale as “high” in cases in which study funding presented a potential conflict of interest.

We created a summary assessment of “Overall Risk of Bias” by grouping the criteria included in the Cochrane tool into four categories based on the nature of their respective threats to validity. The four categories address: (1) participant enrollment (comprising “sequence generation” and “allocation concealment”), (2) blinding (“blinding of participants, personnel and outcome assessors”), (3) outcome data (“incomplete outcome data” and “selective outcome reporting”), and (4) other sources of bias. We then concluded that an individual study was at “high” overall risk of bias if it was assigned a “high” risk rating for one or more discrete criteria in at least two different categories. A study was determined to be at “medium” overall risk of bias if it was assigned a “high” risk rating in only one discrete criterion, or in two criteria within the same category. For example, if a study was at “high” risk of bias for both “sequence generation” and “incomplete outcome data,” the overall risk would be “high” because there is concern about two different categories. Conversely, if a study was at “high” risk of bias for “sequence generation” and “allocation concealment,” then the overall risk would be “medium” because the two criteria are in the same category. If no criteria were assessed to be at “high” risk, then the overall risk of bias was “low.” However, if we rated the risk as “Unclear” in two or more categories, then the overall risk was “unclear.”

## Data Synthesis

We synthesized the data qualitatively. Due to the clinical heterogeneity and the small number of included studies, we did not attempt to combine data from the studies quantitatively using meta-analyses.

We have described outcomes as statistically significant when identified as such by the authors of the primary studies or by the EPC’s calculations from reported data. Statistical significance, however, does not always equate with clinically significant changes in outcomes. In the strength of evidence (SOE) tables, we note any cases in which a statistically significant result was not associated with a minimum important difference (see Appendix D). We calculated effect sizes and 95% confidence intervals for within study comparisons when the publications provided sufficient data.

Critical outcomes for the KQ included the following validated outcomes: asthma-control measures (Asthma Control Questionnaire), asthma-exacerbation measures, asthma-related health care utilization and costs (use of rescue medication), asthma-related pulmonary physiology (forced expiratory volume in 1 second [or as % predicted] and morning peak expiratory flow), and the Asthma Quality of Life Questionnaire. We also considered symptoms reported in other ways and adverse events as critical outcomes.

## Strength of Body of Evidence

We graded the SOE based on the methods guidance established by the EPC program. This approach incorporates five key domains: study limitations, consistency, directness, precision, and reporting bias.

We determined study limitations by appraising the degree to which the included studies had adequate protection against bias (i.e., good internal validity). We downgraded for study limitations when 50 percent or more of the studies evaluated for a given outcome were at “high” overall risk of bias as described above. If the evidence permits a conclusion, then, all else being equal, a set of studies at low risk of bias yields a higher SOE rating than a set of studies at high risk of bias.

We assessed consistency of results for the same outcome among the available studies in terms of the direction and magnitude of effect. We downgraded for inconsistency when there was heterogeneity in the effects of an intervention across studies for a given outcome that could not be explained through identifiable differences in study characteristics. We downgraded for unknown consistency when only a single study was included for an outcome.

The evidence was considered indirect if the populations, interventions, comparisons, or outcomes used within studies did not directly correspond to the comparisons we were evaluating, and we suspected there may be differences in effect based on that indirectness.

Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome and is affected by sample size and number of events and most commonly represented by the width of confidence intervals. We also considered the evidence to be imprecise when key components of the outcome data that studies provided were not fully reported (e.g., measures of variance were not included) or when it was not possible to derive an estimate of effect based on the available data.

Reporting bias includes publication bias, outcome-reporting bias, and analysis-reporting bias. Given the small number of studies we evaluated, we did not examine funnel plots. We downgraded for reporting bias when we detected a likelihood of outcome-reporting bias (important clinical outcomes appear to have been collected but not reported by the studies within a comparison) or analysis reporting bias (important comparisons were not analyzed).

## Applicability

Several a priori factors of this evidence base may limit the applicability of findings. We evaluated the available literature in context with our specific PICOTS criteria and have described differences between them in the Discussion chapter. The major issues related to applicability of this evidence base include patient selection criteria and characteristics as well as the choice of comparators and outcomes reported in the studies.

## Peer Review and Public Commentary

Experts in clinical management of asthma, and strategies to minimize the presence and effect of indoor inhalant allergens, were invited to provide external peer review of the draft report. Agency for Healthcare Research and Quality (AHRQ) staff, an Associate Editor, and representatives from NHLBI reviewed the draft report before it was distributed for peer review. The draft report was also posted on the AHRQ Web site from April 26, 2017, to May 25, 2017, to enable public comment. We revised the report based on peer and public feedback, and noted these revisions in the Disposition of Comments Report. The disposition report is made available 3 months after the final review is posted on the AHRQ Web site.

Several important revisions were made to the report in response to peer review and public comment. As noted above, this review was initially designed to include the current Key Question as well as an additional Key Question addressing the effectiveness of indoor allergen reduction. We separated the larger review into two independent reports in response to substantial feedback. We clarified some of the study characteristics, outcomes, and terminology used throughout the review, and reorganized the results to increase clarity. Finally, we expanded the Discussion to address the important need for further sham-controlled studies.