# Introduction

## Background

Asthma is a chronic inflammatory disorder of the airways, characterized by varying degrees of airflow obstruction. Bronchoconstriction, inflammatory cell infiltration, and airway edema reduce airflow intermittently, often in response to specific exposures, resulting in respiratory symptoms.^1^ In the United States, asthma’s prevalence has increased over the past decade, from an estimated 22.2 million Americans in 2005 to 24 million Americans in 2014.^2,3^ Asthma can significantly affect patients’ and families’ quality of life and ability to pursue activities such as school, work, and exercise. Globally, asthma ranks 14^th^ in prevalence based on the burden of disease, as measured by disability-adjusted life years.^4^ In the United States, asthma contributes significantly to health care resource utilization and associated costs. For example, in 2012, asthma was one of the top 20 leading diagnosis groups for primary care visits and was the main reason for 1.8 million emergency department visits and 439,000 hospitalizations. While the severity of disease varies between patients and over time in the same patient, asthma can be fatal, accounting for approximately 1 death per 100,000 Americans.^5^

### Role of Bronchial Thermoplasty in Management of Asthma

Patients with severe, persistent asthma are managed with multiple medications that may include inhaled, orally administered, and biologic therapeutics. Some of these patients might be eligible for bronchial thermoplasty (BT), an interventional treatment option that involves the delivery of controlled radiofrequency (RF) thermal energy to the walls of accessible proximal airways with the intent of reducing excess smooth muscle tissue in the airways. The Alair™ Bronchial Thermoplasty System (Boston Scientific Corp.) consists of a radiofrequency controller, footswitch, and a patient return electrode, which provides temperature-controlled delivery of RF energy to a disposable, single-use catheter for a predetermined duration. The Alair Catheter was designed for use with high-frequency compatible flexible bronchoscopes, delivering energy to the desired airway site while relaying temperature feedback to the controller. Physicians perform three bronchoscopic procedures to different areas of the lung approximately 3 weeks apart: the lower lobe of the right lung, the lower lobe of the left lung, then both upper lobes in the final procedure. In each procedure, the physician performs about 45 to 60 smooth muscle ablations heating the airway wall to about 150°F for 10 seconds. Each procedure usually takes under an hour. Sedation for BT typically involves a combination of moderate or deep sedation and local anesthesia.^6^ In April 2010, the U.S. Food and Drug Administration approved the Alair BT system for use in patients 18 years of age or older with severe, persistent asthma.

### Purpose of Systematic Review

In 1989, the National Heart, Lung, and Blood Institute (NHLBI) initiated the National Asthma Education and Prevention Program (NAEPP) to address the growing concern about asthma in the United States. One of NAEPP’s first accomplishments was to convene a panel of experts, who produced a report in 1991, The National Asthma Education and Prevention Program Expert Panel Report (EPR): Guidelines for the Diagnosis and Management of Asthma. The guidelines address the diagnosis, evaluation, and treatment of asthma. Given that the most recent report, EPR-3, was published in 2007,^1^ NHLBI assessed the need for an update by requesting information from the public, NAEPP Coordinating Committee Members, its affiliates, and members of the 2007 Expert Panel. Collected information was provided to the NHLBI Advisory Council Asthma Expert Working Group, which produced a report to summarize the process and recommendations from their needs assessment.^7^ The Working Group identified six high-priority topics that should be updated. For each topic, Key Questions meriting a systematic literature review were formulated. NHLBI engaged the Agency for Healthcare Research and Quality to perform the systematic reviews through its Evidence-Based Practice Centers. This document represents the systematic review “Role of Bronchial Thermoplasty in Management of Asthma.”

## Scope and Key Question

This report’s main objective is to conduct a systematic review of the benefits and harms of BT for the management of asthma in adults. In this review, we address the following Key Question (KQ):

Key Question 1 What are the benefits and harms of using BT in addition to standard treatment for the treatment of adult (≥18 years) patients with asthma?

## Analytic Framework

We developed an analytic framework to guide the systematic review process (Figure 1).

Figure 1 Analytic framework for bronchial thermoplasty in asthma

This figure depicts the key question within the context of the PICOTS described above. The figure illustrates how bronchial thermoplasty for adults with severe asthma can be compared with either sham treatment or continued standard care. Ultimately, the figure depicts the long term outcomes of bronchial thermoplasty, which are listed in the box on the right, and include: asthma control, asthma exacerbations, asthma-related healthcare utilization and costs, pulmonary physiology, asthma-related quality of life, and death. Also, the figure depicts harms potentially associated with bronchial thermoplasty, in the oval at the bottom. These include airway irritation or compromise, respiratory tract infections, lung collapse, and hemoptysis.

## Organization of This Report

In the remaining three chapters of this report, we describe the methods for this systematic review, present the results for the KQ, and discuss the overall findings. In the Results chapter, we provide the results of the literature searches and screening procedures, as well as descriptions of included studies, key points, detailed syntheses of the studies, and strength-of-evidence tables for the KQ. The Discussion chapter reviews the key findings and strength of evidence for the KQ, places the findings in the context of previous systematic reviews and clinical practice guidelines, examines the general applicability of the studies, discusses implications for decisionmaking, describes limitations of the systematic review process and the evidence base for the KQ, and identifies knowledge gaps that require further research.

A list of acronyms and abbreviations appears after the references, followed by six appendixes: Appendix A. Search Strategies; Appendix B. Excluded Studies; Appendix C. Evidence Tables; Appendix D. Minimally Important Differences for Asthma Study Outcomes; Appendix E. Ongoing Clinical Trials; and Appendix F. Reference List for Appendixes B, C, and C.