# Peer Reviewers

Before publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Charles Barnes, Ph.D.
  Professor of Pediatrics
  University of Missouri-Kansas City
  Kansas City, MO
- Steve N. Georas, M.D.
  Professor of Medicine
  University of Rochester Medical Center
  Rochester, NY
- Mitchell H. Grayson, M.D.
  Professor and Chief, Division of Allergy and Immunology
  Department of Pediatrics
  Nationwide Children’s Hospital and The Ohio State University School of Medicine
  Columbus, OH
- David Miller, Ph.D.
  Professor of Chemistry
  Carleton University
  Ottawa, ON, Canada