# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Leonard B. Bacharier, M.D.^*^
  Professor of Pediatrics
  Washington University School of Medicine
  St. Louis, MO
- Thomas B. Casale, M.D.^*^
  Professor of Internal Medicine and Pediatrics
  University of South Florida
  Tampa, FL
- Michelle M. Cloutier, M.D.
  Professor Emeritus of Pediatrics
  UCONN Health Founding Director Asthma Center, Connecticut Children’s Medical Center
  Hartford, CT
- Anne Fitzpatrick, Ph.D.^*^
  Emory University, Department of Pediatrics
  Children’s Healthcare of Atlanta
  Atlanta, GA
- Theresa W. Guilbert, M.D., M.S.
  Professor of Pulmonary Medicine and Pediatrics
  Cincinnati Children’s Hospital
  Cincinnati, OH
- Monica Kraft, M.D.
  Chair, Department of Medicine
  University of Arizona College of Medicine
  Tucson, AZ
- Elizabeth C. Matsui, M.D., M.P.H.^*^
  Professor of Pediatrics
  Johns Hopkins University
  Baltimore, MD
- Wanda Phipatanakul, M.D., M.S.
  Associate Professor of Pediatrics
  Boston Children’s Hospital
  Boston, MA
- Michael E. Wechsler, M.D., M.M.Sc.^*^
  Professor of Medicine
  National Jewish Health
  Denver, CO

* Provided input on Draft Report