# Acknowledgments

The authors gratefully acknowledge Mary Butler, Ph.D., M.B.A., who served as Associate Editor, and the following individuals at ECRI Institute for their contributions to this project: Katherine Donahue, Gina Giradi, M.S., and Kristy McShea, M.S.L.I.S.

We also thank AHRQ Task Order Officers, Aysegul Gozu, M.D., M.P.H., and David W. Niebuhr, M.D., M.P.H. M.Sc., and the following individuals at National Heart, Lung, and Blood Institute (NHLBI): Janet M. DeJesus, M.S., Michelle Freemer, M.D., M.P.H., and Rachael L. Tracy, M.P.H. We appreciate the collaboration of our colleagues at other EPCs preparing reports for NHLBI, and particularly thank Diana Sobieraj and others at the University of Connecticut EPC, who provided the table and references for minimally important differences in Appendix D.