# Appendix F Reference List for Appendixes B, C, and D

1 Castro M, Rubin AS, Laviolette M, . Effectiveness and safety of bronchial thermoplasty in the treatment of severe asthma: a multicenter, randomized, double-blind, sham-controlled clinical trial. Am J Respir Crit Care Med. 2010 Jan 15;181(2):116–24. Also available: http://dx.doi.org/10.1164/rccm.200903-0354OC. PMID: 19815809.19815809
2 Pavord ID, Cox G, Thomson NC, . Safety and efficacy of bronchial thermoplasty in symptomatic, severe asthma. Am J Respir Crit Care Med. 2007 Dec 15;176(12):1185–91. Also available: http://dx.doi.org/10.1164/rccm.200704-571OC. PMID: 17901415.17901415
3 Cox G, Thomson NC, Rubin AS, . Asthma control during the year after bronchial thermoplasty. New Eng J Med. 2007 Mar 29;356(13):1327–7. Also available: http://dx.doi.org/10.1056/NEJMoa064707. PMID: 17392302.17392302
4 Thomson NC, Rubin AS, Niven RM, . Long-term (5 year) safety of bronchial thermoplasty: asthma intervention research (AIR) trial. BMC Pulm Med. 2011 Feb 11;11:8. Also available: http://dx.doi.org/10.1186/1471-2466-11-8. PMID: 21314924.21314924
5 Bicknell S, Chaudhuri R, Lee N, . Effectiveness of bronchial thermoplasty in severe asthma in ‘real life’ patients compared with those recruited to clinical trials in the same centre. Ther Adv Respir Dis. 2015 Dec;9(6):267–71. Epub 2015 Aug 24. Also available: http://dx.doi.org/10.1177/1753465815601332. PMID: 26307767.26307767
6 Pavord ID, Thomson NC, Niven RM, . Safety of bronchial thermoplasty in patients with severe refractory asthma. Ann Allergy Asthma Immunol. 2013 Nov;111(5):402–7. Also available: http://dx.doi.org/10.1016/j.anai.2013.05.002. PMID: 24125149.24125149
7 Wechsler ME, Laviolette M, Rubin AS, . Bronchial thermoplasty: long-term safety and effectiveness in patients with severe persistent asthma. J Allergy Clin Immunol. 2013 Dec;132(6):1295–302. Epub 2013 Aug 30. PMID: 23998657.23998657
8 McCambridge J, Kruklitis R. Transient bronchial wall thickening after bronchial thermoplasty for asthma. J Bronchology Interv Pulmonol. 2016 Jan;23(1):51–3. Also available: http://dx.doi.org/10.1097/LBR.0000000000000240. PMID: 26705012.26705012
9 Nguyen DV, Murin S. Bronchial artery pseudoaneurysm with major hemorrhage after bronchial thermoplasty. Chest. 2016 Apr;149(4):e95–7. Also available: http://dx.doi.org/10.1016/j.chest.2015.09.016. PMID: 27055718.27055718
10 Balu A, Ryan D, Niven R. Lung abscess as a complication of bronchial thermoplasty. J Asthma. 2015 Aug 9;52(7):740–2. Also available: http://dx.doi.org/10.3109/02770903.2015.1005844. PMID: 25766745.25766745
11 Facciolongo N, Menzella F, Lusuardi M, . Recurrent lung atelectasis from fibrin plugs as a very early complication of bronchial thermoplasty: a case report. Multidiscip Respir Med. 2015;10(1):9. Also available: http://dx.doi.org/10.1186/s40248-015-0002-7. PMID: 25852934.25852934
12 Doeing DC, Husain AN, Naureckas ET, . Bronchial thermoplasty failure in severe persistent asthma: a case report. J Asthma. 2013 Sep;50(7):799–801. Also available: http://dx.doi.org/10.3109/02770903.2013.796974. PMID: 23651158.23651158
13 Doeing DC, Mahajan AK, White SR, . Safety and feasibility of bronchial thermoplasty in asthma patients with very severe fixed airflow obstruction: a case series. J Asthma. 2013 Mar;50(2):215–8. Also available: http://dx.doi.org/10.3109/02770903.2012.751997. PMID: 23252954.23252954
14 Mahajan AK, Hogarth DK. Bronchial thermoplasty: therapeutic success in severe asthma associated with persistent airflow obstruction. J Asthma. 2012 Jun;49(5):527–9. Also available: http://dx.doi.org/10.3109/02770903.2012.676124. PMID: 22515527.22515527
15 Cox G, Miller JD, McWilliams A, . Bronchial thermoplasty for asthma. Am J Respir Crit Care Med. 2006 May;173(9):965–9. Also available: http://dx.doi.org/10.1164/rccm.200507-1162OC. PMID: 16456145.16456145
16 Schatz M, Kosinski M, Yarlas AS, . The minimally important difference of the Asthma Control Test. J Allergy Clin Immunol. 2009 Oct;124(4):719–23.e1. Also available: http://dx.doi.org/10.1016/j.jaci.2009.06.053. PMID: 19767070.19767070
17 Juniper EF, Svensson K, Mörk AC, . Measurement properties and interpretation of three shortened versions of the asthma control questionnaire. Respir Med. 2005 May;99(5):553–8. Also available: http://dx.doi.org/10.1016/j.rmed.2004.10.008. PMID: 15823451.15823451
18 Juniper EF, Gruffydd-Jones K, Ward S, . Asthma Control Questionnaire in children: validation, measurement properties, interpretation. Eur Respir J. 2010 Dec;36(6):1410–6. Also available: http://dx.doi.org/10.1183/09031936.00117509. PMID: 20530041.20530041
19 Juniper EF, Buist AS, Cox FM, . Validation of a standardized version of the Asthma Quality of Life Questionnaire. Chest. 1999 May;115(5):1265–70. PMID: 10334138.10334138
20 Juniper EF, Guyatt GH, Cox FM, . Development and validation of the Mini Asthma Quality of Life Questionnaire. Eur Respir J. 1999 Jul;14(1):32–8. PMID: 10489826.10489826
21 Juniper EF, Guyatt GH, Willan A, . Determining a minimal important change in a disease-specific Quality of Life Questionnaire. J Clin Epidemiol. 1994 Jan;47(1):81–7. PMID: 8283197.8283197
22 Juniper EF, Svensson K, Mörk AC, . Modification of the asthma quality of life questionnaire (standardised) for patients 12 years and older. Health Qual Life Outcomes. 2005 Sep 16;3:58. Also available: http://dx.doi.org/10.1186/1477-7525-3-58. PMID: 16168050.16168050
23 Wyrwich KW, Ireland AM, Navaratnam P, . Validation of the AQLQ12+ among adolescents and adults with persistent asthma. Qual Life Res. 2011 Aug;20(6):903–12. Also available: http://dx.doi.org/10.1007/s11136-010-9821-3. PMID: 21184185.21184185
24 Juniper EF, Guyatt GH, Feeny DH, . Measuring quality of life in children with asthma. Qual Life Res. 1996 Feb;5(1):35–46. PMID: 8901365.8901365
25 Juniper EF, Guyatt GH, Feeny DH, . Measuring quality of life in the parents of children with asthma. Qual Life Res. 1996 Feb;5(1):27–34. PMID: 8901364.8901364
26 Santanello NC, Zhang J, Seidenberg B, . What are minimal important changes for asthma measures in a clinical trial? Eur Respir J. 1999 Jul;14(1):23–7. PMID: 10489824.10489824