# Appendix E Ongoing Clinical Trials

Table E-1 Ongoing clinical trials

Study Name NCT Identifier Sponsor | Planned Enrollment | Study Design and Objective Primary Endpoints | Estimated Final Completion Date
RISA Extension Study - Long Term Safety [underlined: NCT00401986] Asthmatx, Inc. | n=15 patients with severe uncontrolled asthma; enrollment limited to patients who participated in the RISA Trial ([underlined: NCT00214539]). | Prospective observational cohort study evaluating long-term safety of BT Primary endpoint: Not provided | No completion date provided; status of trial is listed as unknown, but is linked to Pavord et al. 2013^6^
Efficacy of Bronchial Thermoplasty in Korean [underlined: NCT02031263] Asan Medical Center | n=9 patients with severe uncontrolled asthma | Open-label, single-arm trial investigating the safety and efficacy of BT in a Korean population Primary endpoint: Changes in the Quality of Life Questionnaire for Adult Korean Asthmatics from baseline to 3 month post-treatment | February 2015 The status of this trial is unknown
Bronchial Thermoplasty: Effect on Neuronal and Chemosensitive Component of the Bronchial Mucosa [underlined: NCT01839591] Arcispedale Santa Maria Nuova-IRCCS | n=12 patients with severe uncontrolled asthma | Open-label, single-arm trial investigating the safety and efficacy of BT, and the impact of BT on potential sources of bronchospasm in the bronchial mucosa Primary endpoint: Changes in ACT and AQLQ scores from baseline to one year post-treatment | December 2015 The status of this trial is unknown
Spirometric Response to Bronchial Thermoplasty in Patients With Severe Asthma [underlined: NCT02241265] University of Oklahoma | n=20 patients with severe asthma | Open-label, single-arm trial assessing the impact of BT on FEV_1_ Primary endpoint: Changes in prebronchodilator FEV_1_ and FVC from baseline to 12 months post-treatment | July 2016 The status of this trial is unknown
Study of Physiopathological Mechanisms and Results of Treatment With Bronchial Thermoplasty in Severe Asthma [underlined: NCT01974921] Fundació Institut de Recerca de l’Hospital de la Santa Creu i Sant Pau | n=15 patients with severe asthma and at least 2 exacerbations in the past year | Open-label, single-arm trial investigating the safety, efficacy, and histology of BT Primary endpoint: Changes in bronchial smooth muscle from baseline to 6 months post-treatment | September 2016 This trial is listed as still recruiting
Bronchial Thermoplasty for Severe Asthmatics Guided by HXe MRI [underlined: NCT01832363] Xemed LLC Collaborators: National Institutes of Health (NIH) National Heart, Lung, and Blood Institute (NHLBI) Washington University School of Medicine University of Virginia | n=30 patients with severe asthma | Double-blind (patient, outcome assessor) RCT to determine the utility of using hyperpolarized xenon (HXe) lung MRI to guide BT (HXe-guided BT vs. Standard BT) Primary endpoint: Change in AQLQ scores from baseline to 2.5 years post-treatment | August 2017
Bicentric Prospective Study, Evaluating Bronchial Thermoplasty in a Patient Presenting Severe Uncontrolled Asthma (ASMATHERM) [underlined: NCT01777360] Assistance Publique - Hôpitaux de Paris Collaborator: Boston Scientific Corporation | n=46 patients with severe uncontrolled asthma receiving optimal treatment and experiencing at least one exacerbation requiring oral steroids in the past year | Open-label, single-arm trial designed to determine which patients might be “best candidates” for BT Primary endpoint: Reduction in smooth muscle surface area from baseline to 3 months post-treatment | September 2017
Effect of Bronchial Thermoplasty on Moderate Bronchial Asthma in China [underlined: NCT02965807] Guangzhou Institute of Respiratory Disease | n=50 patients with moderate asthma | Open-label, single-arm trial investigating the safety and efficacy of BT Primary endpoint: Change in AQLQ from baseline over a 12-month period | December 2017
Unravelling Targets of Therapy in Bronchial Thermoplasty in Severe Asthma (TASMA) [underlined: NCT02225392] Academisch Medisch Centrum - Universiteit van Amsterdam (AMC-UvA) Collaborators: ZonMw: The Netherlands Organisation for Health Research and Development The Netherlands Asthma Foundation Boston Scientific Corporation | n=40 patients with severe asthma | Non-blinded RCT comparing patients who undergo immediate BT to a control group (BT delayed until after primary endpoint for immediate BT group—25 weeks) Primary endpoint: Change in ASM mass between BT treated and control (25 weeks) | April 2018
Bronchial Thermoplasty: Mechanism of Action and Defining Asthma Phenotype [underlined: NCT02075151] National University Hospital, Singapore | n=50 patients with poorly controlled severe asthma (ACT score <20 even with use of >500 mcg fluticasone/d or >800 mcg budesonide/d) | Open-label, single-arm trial investigating the safety and efficacy of BT Primary endpoint: Change in ACT scores from baseline over a 2-year period | May 2018
Bronchial Thermoplasty in Severe Asthma With Frequent Exacerbations (THERMASCORT) [underlined: NCT02464995] University Hospital, Strasbourg, France | n=34 with severe asthma and frequent severe exacerbations (4 or more episodes requiring systemic steroids for more than 3 days) in the past year | Non-blinded RCT comparing patients who undergo BT + medical management to those receiving medical management alone Primary endpoint: Change in severe exacerbations from baseline over a 12-month period | November 2018
Bronchial Thermoplasty Global Registry [underlined: NCT02104856] Boston Scientific Corporation | n=160 patients undergoing BT according to labeled indications | Observational patient registry following patient outcomes in “real world” BT patients Primary endpoint: Proportion of patients experiencing severe exacerbations up to 2 years post-treatment | June 2019
China Alair System Registry Study-CARE Study [underlined: NCT02206269] BSC International Medical Trading (Shanghai) Co., Ltd. | n=225 patients with severe persistent asthma undergoing BT according to labeled indications | Observational patient registry following patient outcomes in “real world” BT patients Primary endpoint: Rates of severe asthma exacerbations following BT with the Alair System up to 1 year post-treatment | June 2019
Bronchial Thermoplasty for Severe Asthma With Dynamic Hyperinflation (HEAT-SA) [underlined: NCT02618551] University Hospital, Toulouse | n=15 patients with uncontrolled severe asthma receiving optimal treatment and who experienced at least 2 exacerbations requiring systemic steroids in the past year | Open-label, single-arm trial investigating the impact of BT on dynamic hyperinflation phenomenon, which is a worsening of bronchial obstruction following exercise Primary endpoint: Change in dynamic hyperinflation from baseline to 3 months post-BT | December 2018
Hyperpolarized Magnetic Resonance Imaging in Asthma Pre- and Post-Bronchial Thermoplasty [underlined: NCT02263794] Dr. Grace Parraga, University of Western Ontario, Canada | n=14 patients with severe asthma | RCT comparing conventional BT to image-guided BT (Outcome assessor-blinded study) Primary endpoint: Whole lung and lobe specific VDP | December 2019
Bronchial Thermoplasty in Severe Persistent Asthma [underlined: NCT01350336] Boston Scientific Corporation | n=284 patients with severe persistent asthma | Open-label, single arm post-marketing study intended to assess long-term safety and durability of BT efficacy in patients 18 years and older with severe persistent asthma Primary endpoint: Proportion of patients experiencing severe exacerbations up to 5 years post-treatment | January 2020
A Prospective Observational Study of Biopredictors of Bronchial Thermoplasty Response in Patients With Severe Refractory Asthma (BTR Study) [underlined: NCT01185275] Washington University School of Medicine Collaborators: The Cleveland Clinic National Jewish Health University of Arizona University of Chicago Louisiana State University Health Sciences Center in New Orleans University of Alabama at Birmingham Creighton University | n=190 patients with severe asthma | Prospective observational cohort study evaluating the role of baseline clinical, physiologic, biologic and imaging markers in clinical response to BT Primary endpoint: Improvement in asthma quality of life 12 months post-treatment | August 2020
Unraveling Targets of Therapy in Bronchial Thermoplasty in Severe Asthma (TASMA) Extension Study [underlined: NCT02975284] Extension study of [underlined: NCT02225392] Academisch Medisch Centrum - Universiteit van Amsterdam (AMC-UvA) Collaborator: University Medical Center Groningen | n=40 patients with severe asthma | Prospective observational cohort study evaluating long-term (5 years) clinical outcomes in patients enrolled in the TASMA RCT Primary endpoint: Rates of severe exacerbations, emergency room visits and/or hospitalizations for respiratory symptoms up to 5 years post-treatment | September 2024

ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; ASM=airway smooth muscle; BT=bronchial thermoplasty; FEV_1_=forced expiratory volume; FVC=forced vital capacity; HXe MRI=hyperpolarized xenon-129 magnetic resonance imaging; RCT=randomized controlled trial; RISA=Research in Severe Asthma Trial; VDP=ventilation defect percent