# Appendix D Minimally Important Differences for Asthma Study Outcomes

It is important to evaluate whether a measured change in an asthma outcome is clinically meaningful as well as statistically significant. Thresholds for determining clinically significant improvement have been established for some measures of asthma control, asthma-related quality of life, pulmonary physiology, and healthcare utilization, and are presented in Table E-1. The data in this table are reproduced with permission from the AHRQ EPC report, “Systematic Review of Intermittent Inhaled Corticosteroids and of Long-acting Muscarinic Antagonists for Asthma,” by the University of Connecticut Evidence-based Practice Center.

Table D-1 Thresholds for clinical significance

Instrument/Outcome | Range (points) | Final score | Threshold
ACT | 5 to 25 | Well controlled: ≥20 Not well controlled: ≤19 | ≥12 y: Δ 3 points^16^
ACQ5, ACQ6 | 0 to 6 | Uncontrolled: ≥1.5 Well-controlled: <0.75 | ≥18 y: Δ 0.5 points^17^
ACQ7 | 0 to 6 | Uncontrolled: ≥1.5 Well-controlled: <0.75 | ≥6 y: Δ 0.5 points^17,18^
AQLQ,AQLQ(S), AQLQ-mini | 1 to 7 | Severe impairment = 1 No impairment= 7 | ≥18 y: Δ 0.5 points^19–21^
AQLQ12+ | 1 to 7 | Severe impairment = 1 No impairment= 7 | ≥12 y: Δ 0.5 points^22,23^
PAQLQ, PACQLQ | 1 to 7 | Severe impairment = 1 No impairment= 7 | 7–17 y: Δ 0.5 points^24,25^
FEV1 | Continuous measure, L | NA | ≥18 y: −0.2 L^26^
Rescue medication use | Continuous measure, puffs per unit of time | NA | ≥18 y: −0.81 puffs/day^26^

ACT=asthma control test; ACQ=asthma control questionnaire; AQLQ=asthma quality of life questionnaire;

AQLQ-mini=asthma quality of life questionnaire-15 items;

AQLQ(S)=Sydney asthma quality of life questionnaire or Asthma quality of life questionnaire-standardized version

AQLQ12+=asthma quality of life questionnaire with standardized activities (12 and older); FEV_1_=forced expiratory volume; NA=not available; PACQLQ=pediatric asthma caregiver’s quality of life questionnaire; PAQLQ=pediatric asthma quality of life questionnaire