# Appendix C Evidence Tables

## Key Question What are the benefits and harms of using bronchial thermoplasty in addition to standard treatment for the treatment of adult (≥18 years) patients with severe asthma?

Table C-1 Study characteristics of comparative trials

Table C-2 Outcomes of comparative bronchial thermoplasty studies and associated followup studies

Table C-3 Risk of bias assessment for included RCTs

Table C-4 Strength of evidence assessments

Table C-5 Study and patient characteristics of descriptive studies (case reports and case series)

Table C-6 Outcomes of descriptive bronchial thermoplasty studies (case reports and case series)