# Appendix B Excluded Studies

Ryan DM, Fowler SJ, Niven RM. Reduction in peripheral blood eosinophil counts after bronchial thermoplasty. J Allergy Clin Immunol. 2016 Mar 4. Also available: http://dx.doi.org/10.1016/j.jaci.2015.11.044. PMID: 26953157. Single-arm study; no adverse events26953157
Zhou JP, Feng Y, Wang Q, . Long-term efficacy and safety of bronchial thermoplasty in patients with moderate-to-severe persistent asthma: A systemic review and meta-analysis. J Asthma. 2016 Jan 2;53(1):94–100. Also available: http://dx.doi.org/10.3109/02770903.2015.1065424. Systematic review of included individual studies^1–3^26383773
Ansarin K, Attaran D, Jamaati H, . Approach to patients with severe asthma: a consensus statement from the Respiratory Care Experts’ Input Forum (RC-EIF), Iran. Tanaffos. 2015;14(2):73–94. PMID: 26528362. Consensus statement26528362
Chakir J, Haj-Salem I, Gras D, . Effects of bronchial thermoplasty on airway smooth muscle and collagen deposition in asthma. Ann Am Thorac Soc. 2015 Sep 1;12(11):1612–8. Also available: http://dx.doi.org/10.1513/AnnalsATS.201504-208OC. PMID: 26325484. Single-arm study; no adverse events26325484
Denner DR, Doeing DC, Hogarth DK, . Airway inflammation after bronchial thermoplasty for severe asthma. Ann Am Thorac Soc. 2015 Sep 1;12(9):1302–9. Also available: http://dx.doi.org/10.1513/AnnalsATS.201502-082OC. Single-arm study; no adverse events26230374
Dheda K, Koegelenberg CF, Esmail A, . Recommendations for the use of bronchial thermoplasty in the management of severe asthma. S Afr Med J. 2015 Sep;105(9):726–32. PMID: 26428967. Systematic review of included individual studies^1–3^26428967
Grant MD, Blue Cross Blue Shield Association. Bronchial thermoplasty for treatment of inadequately controlled severe asthma. Technol Eval Cent Asses Program Exec Summ. 2015 Mar;29(12):1–5. PMID: 25962190. Systematic review of included individual studies^1–3^25962190
Torrego A, Sola I, Munoz AM, . Bronchial thermoplasty for moderate or severe persistent asthma in adults. Cochrane Database Syst Rev. 2014;3(3):CD009910. PMID: 24585221. Systematic review of included individual studies^1–3^24585221
Castro M, Rubin A, Laviolette M, . Persistence of effectiveness of bronchial thermoplasty in patients with severe asthma. Ann Allergy Asthma Immunol. 2011 Jul;107(1):65–70. Also available: http://dx.doi.org/10.1016/j.anai.2011.03.005. PMID: 21704887. Superseded by related study with longer followup^4^21704887
Wu Q, Xing Y, Zhou X, . Meta-analysis of the efficacy and safety of bronchial thermoplasty in patients with moderate-to-severe persistent asthma. J Int Med Res. 2011;39(1):10–22. PMID: 21672303. Systematic review of included individual studies^1–3^21672303