# Appendix A Search Strategies

## Resources Searched

ECRI Institute information specialists searched the following databases for relevant information. Search terms and strategies for each resource appear below.

Table A-1 Databases searched

Name | Date Limits | Platform/Provider
The Cochrane Central Register of Controlled Trials (CENTRAL) | Inception [1999] through April 20, 2017 | Wiley
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Inception [1999] through April 20, 2017 | Wiley
Cumulative Index of Nursing and Allied Health Literature (CINAHL) | Inception [1981] through April 20, 2017 | EBSCOhost
Database of Abstracts of Reviews of Effects (DARE) (part of the Cochrane Library) | Inception [1999] through April 20, 2017 | Wiley
EMBASE (Excerpta Medica) | Inception [1966] through April 20, 2017 | Embase.com
Health Technology Assessment Database (HTA) (part of the Cochrane Library) | Inception [1999] through April 20, 2017 | Wiley
MEDLINE | Inception [1966] through April 20, 2017 | Embase.com
PUBMED (In Process citations) | Inception [1966] through April 20, 2017 | NLM
U.K. National Health Service Economic Evaluation Database (NHS EED) (part of the Cochrane Library) | Inception [1999] through April 20, 2017 | Wiley
Associations and Societies
American Academy of Allergy, Asthma, and Immunology | June 29, 2016 | https://www.aaaai.org/
Asthma and Allergy Foundation of America | June 30, 2016 | http://www.aafa.org/
American College of Allergy, Asthma, and Immunology | June 29, 2016 | http://acaai.org/
Agency for Healthcare Research and Quality Technology Assessment Program | June 29, 2016 | http://www.ahrq.gov/research/findings/ta/index.html
American Lung Association | June 29, 2016 | http://www.lung.org/
American Thoracic Society | June 29, 2016 | https://www.thoracic.org/
Centers for Disease Control and Prevention | June 28, 2016 | https://www.cdc.gov/
National Academy of Medicine | June 28, 2016 | https://nam.edu/
National Heart, Lung, and Blood Institute | June 30, 2016 | https://www.nhlbi.nih.gov/
Other Gray Literature Resources
ClinicalTrials.gov | Searched April 20, 2017 | NIH
Centers for Medicare and Medicaid (CMS) - Medicare Coverage Database | Searched July 14, 2016 | CMS
ECRI Institute Library Catalog | Searched June 24, 2016 | ECRI Institute
ECRI Institute Members Website | Searched June 24, 2016 | ECRI Institute
Health Devices | Searched June 24, 2016 | ECRI Institute
Healthcare Standards | Searched June 24, 2016 | ECRI Institute
Internet | Searched June 27, 2016 | Google; Bing
Manufacturers | Searched June 24, 2016 | Boston Scientific
Medscape | Searched June 22, 2016 | WebMD
National Guideline Clearinghouse™ | Searched June 24, 2016 | AHRQ
National Institute for Health and Care Excellence, U.K. | Searched June 24, 2016 | NHS
TRIP (Turning Research Into Practice) Database | Searched June 27, 2016 | Trip Database, Ltd.
U.S. Food and Drug Administration (FDA), including Medical Device databases | Searched April 20, 2017 | FDA

### Reimbursement

The following Web sites were searched for reimbursement policies: Aetna, Anthem BCBS, BCBS Florida, BCBS of Illinois, BCBS of Texas, BCBS of California, CIGNA, Humana, United Healthcare, Regence.

### Hand Searches of Journal and Gray Literature

Journals and supplements maintained in ECRI Institute’s collections were routinely reviewed. Nonjournal publications from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

### Topic-Specific Search Terms

The search strategies employed combinations of free-text keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. Strategies for each bibliographic database follow this table.

Table A-2 Topic-specific search terms

Concept | Controlled Vocabulary | Keywords
Asthma | EMBASE (EMTREE) asthma/exp ‘allergic asthma’/exp ‘asthmatic state’/exp ‘extrinsic asthma’/exp ‘intrinsic asthma’/exp ‘mild intermittent asthma’/exp ‘mild persistent asthma’/exp ‘nocturnal asthma’/exp ‘occupational asthma’/exp ‘severe persistent asthma’/exp MEDLINE/PubMed(MeSH) Asthma[mh] CINAHL (MH “Asthma+”) (MH “Asthma, Occupational”) | Asthma*
General Allergy terms | EMBASE (EMTREE) allergen/exp ‘disease exacerbation’/exp ‘environmental exposure’/exp ‘health hazard’/exp MEDLINE/PubMed (MeSH) Allergens[mh] “environmental exposure”[mh] CINAHL (MH “Allergens+”) (MH “Disease Exacerbation”) (MH “Environmental Exposure+”) | Allergen exacerbation exacerbate irritant sensitive sensitivity trigger
Bronchial Thermoplasty | EMBASE (EMTREE) ‘bronchial thermoplasty device’/exp MEDLINE/PubMed (MeSH) No equivalent MeSH terms CINAHL No equivalent controlled term | Alair* asthmatx Bronchial thermoplasty bronchiothermoplasty
Bronchial Disease | EMBASE (EMTREE) bronchoscopy/exp bronchoscope/exp bronchoconstriction/exp bronchospasm/exp ‘bronchus disease’/exp bronchus/exp bronchoplasty/exp ‘airway smooth muscle cell’/exp MEDLINE/PubMed (MeSH) bronchoscopy[mh] bronchoscopes[mh] bronchoconstriction[mh] or “bronchial spasm”[mh] “bronchial diseases”[mh] bronchi[mh] CINAHL (MH “Bronchoscopy”) (MH “Bronchoconstriction”) (MH “Bronchial Diseases+”) (MH “Bronchial Spasm”) (MH “Bronchi+”) | airway smooth muscle bronchial constriction bronchial spasm bronchoscope bronchoconstriction bronchospasm bronchus constriction bronchus spasm
Radiofrequency ablation terms | EMBASE (EMTREE) ‘radiofrequency ablation’/exp ‘radiofrequency ablation device’/exp ‘catheter ablation’/exp ‘pulsed radiofrequency treatment’/exp MEDLINE/PubMed (MeSH) “Catheter Ablation”[mh] “Pulsed Radiofrequency Treatment”[mh] CINAHL (MH “Catheter Ablation”) | catheter ablation heat ablation radiofrequency ablation rf ablation thermal ablation thermoplasty

## Search Strategies

Table A-3 Embase/MEDLINE

Set Number | Concept | Search Statement
1 | Bronchial Thermoplasty | ‘bronchial thermoplasty device’/exp OR Alair* OR bronchothermoplast* OR asthmatx* OR bronchiothermoplast* OR (bronchial AND thermoplast*)
2 | Asthma | asthma/exp OR asthma*
3 | Bronchial disease | ‘bronchoscopy’/exp OR ‘bronchoscope’/exp OR ‘bronchoconstriction’/exp OR ‘bronchospasm’/exp OR ‘bronchus disease’/exp OR ‘bronchus’/exp OR ‘bronchoplasty’/exp OR ‘airway smooth muscle cell’/exp OR bronchoscop* OR bronchoconstrict* OR bronchospasm* OR ((bronchial OR bronchus OR bronchi) NEAR/4 (constrict OR spasm*)) OR “airway smooth muscle”
4 | Combine Sets – asthma and/or bronchial disease | 2 OR 3
5 | Radiofrequency ablation terms | ‘radiofrequency ablation’/exp OR ‘radiofrequency ablation device’/exp OR ‘catheter ablation’/exp OR ‘pulsed radiofrequency treatment’/exp OR thermoplast* OR ((radiofrequency OR thermal OR heat OR catheter* OR “RF”) NEAR/4 ablat*)
6 | Combine sets | 4 AND 5
7 | Combine sets | 1 OR 6
8 | Remove unwanted publication types | 7 NOT (abstract:nc OR annual:nc OR book/de OR conference:nc OR ‘conference abstract’:it OR ‘conference paper’/de OR ‘conference paper’:it OR ‘conference proceeding’:pt OR ‘conference review’:it OR congress:nc OR editorial/de OR editorial:it OR erratum/de OR letter:it OR note/de OR note:it OR meeting:nc OR sessions:nc OR ‘short survey’/de OR symposium:nc)
9 | Limit 8 to Humans; | 8 AND [humans]/lim

### EMBASE.com Syntax

* | = | truncation character (wildcard)
NEAR/n | = | search terms within a specified number (n) of words from each other in any order
NEXT/n | = | search terms within a specified number (n) of words from each other in the order specified
/ | = | search as a subject heading
exp | = | “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy)
mj | = | denotes a term that has been searched as a major subject heading
:de | = | search in the descriptors field (controlled terms and keywords)
:lnk | = | floating subheading
/lim | = | limiter
:it,pt. | = | source item or publication type
:ti. | = | limit to title
:ti,ab. | = | limit to title and abstract fields

## PubMed (PreMEDLINE)

Table A-4 PubMed in process citations

Set Number | Concept | Search Statement
1 | Bronchial Thermoplasty | Alair* OR bronchothermoplast* OR asthmatx* OR bronchiothermoplast* OR (bronchial AND thermoplast*)
2 | Asthma | Asthma[mh] OR asthma*
3 | Bronchial disease | “Bronchoscopy”[Mesh] OR “Bronchoscopes”[Mesh] OR “Bronchoconstriction”[Mesh] OR “Bronchial Spasm”[Mesh] OR “Bronchial Diseases”[Mesh] OR “Bronchi”[Mesh] OR bronchoscop* OR bronchoconstrict* OR bronchospasm* OR ((bronchial[tiab] OR bronchus[tiab] OR bronchi[tiab]) AND (constrict[tiab] OR spasm*[tiab])) OR “airway smooth muscle”
4 | Combine Sets – asthma and/or bronchial disease | 2 OR 3
5 | RF ablation terms | “Catheter Ablation”[Mesh] OR “Pulsed Radiofrequency Treatment”[Mesh] OR thermoplast* OR ((radiofrequency OR thermal OR heat OR catheter*) AND ablat*) OR “rf ablation”
6 | Combine sets | 4 AND 5
7 | Combine sets | 1 OR 6
8 | Remove unwanted publication types | 7 NOT (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt] OR “Textbooks” [pt] OR “Book Reviews”[pt]OR “Book Illustrations”[pt] OR book OR books OR textbook*)
9 | In process citations | 8 AND (“inprocess”[sb] OR publisher[sb] OR pubmednotmedline[sb])

### PubMed Syntax

* | = | truncation character (wildcard)
[mh]/[MesH] | = | controlled vocabulary term
[sb] | = | subset
[ti] | = | limit to title field
[tiab] | = | limit to title and abstract fields
[tw] | = | text word

## CINAHL

Table A-5 CINAHL

Set Number | Concept | Search Statement
1 | Bronchial Thermoplasty | Alair* OR bronchothermoplast* OR asthmatx* OR bronchiothermoplast* OR (bronchial AND thermoplast*)
2 | Asthma | (MH “Asthma+”) OR asthma*
3 | Bronchial disease | (MH “Bronchoscopy”) OR (MH “Bronchoconstriction”) OR (MH “Bronchial Diseases+”) OR (MH “Bronchial Spasm”) OR (MH “Bronchi+”) OR bronchoscop* OR bronchoconstrict* OR bronchospasm* OR ((bronchial OR bronchus OR bronchi) AND (constrict* OR spasm*)) OR “airway smooth muscle”
4 | Combine Sets – asthma and/or bronchial disease | 2 OR 3
5 | RF ablation terms | (MH “Catheter Ablation”) OR thermoplast* OR ((radiofrequency OR thermal OR heat OR catheter*) AND ablat*) OR “rf ablation” OR “rf-ablation”
6 | Combine sets | 4 AND 5
7 | Combine sets | 1 OR 6
8 | Remove Medline records

### CINAHL Syntax

…+ | = | explode
* | = | truncation character (wildcard)
Nn | = | search terms within a specified number (n) of words from each other in any order
TI | = | limit to title field
AB | = | limit to title and abstract fields
MH | = | MeSH heading
MJ | = | MeSH heading designated as major topic
PT | = | publication type