# Abbreviations and Acronyms

ACQ: Asthma Control Questionnaire
ACT: Asthma Control Test
AHRQ: Agency for Healthcare Research and Quality
AIR: Asthma Intervention Research Trial
AIR 2: Asthma Intervention Research Trial 2
AQLQ: Asthma Quality of Life Questionnaire
BT: bronchial thermoplasty
CI: confidence interval
ED: emergency department
EPC: Evidence-based Practice Center
EPR: Expert Panel Report
FDA: U.S. Food and Drug Administration
FEV_1_: forced expiratory volume in one second
KQ: Key Question
GRADE: Grading of Recommendations Assessment, Development and Evaluation
MID: minimally important difference
NAEPP: National Asthma Education and Prevention Program
NHLBI: National Heart, Lung, and Blood Institutes
PEF: peak expiratory flow
PICOTS: patient populations, interventions, comparators, outcomes, timing, and settings
PPS: posterior probability of superiority
RCT: randomized clinical trial
RISA: Research in Severe Asthma Trial
SOE: strength of evidence
TEP: Technical Expert Panel