# Results

## Introduction

We begin by describing the results of our literature searches. We then provide a brief general description of the included studies, followed by key summary points. Next, we provide a detailed analysis of the results for the single intervention studies, followed by the multicomponent studies. Finally, we present the results of the qualitative comparative analysis (QCA).

## Results of Literature Searches

The literature searches identified 93 articles appropriate for comprehensive full-text review (see Figure 2). Seventy-two publications addressed the Key Question. The evidence base includes 60 randomized controlled trials (RCT) with data published in 64 articles and 8 non-RCTs. Articles that were excluded at the full-text level with reasons for their exclusion are listed in Appendix B.

Figure 2 Study attrition diagram

KQ=Key Question; RCT=randomized controlled trial

Figure 2 shows a study flow diagram. The large number of citations identified by the literature searches (3,182) enters the flow diagram at the top. These citations are screened by title, with the number excluded (1,261) listed in a box to the right. Abstract screening then occurs, and the citations excluded during abstract screening (1,720) exit the flow diagram to the right. Continuing down the flow diagram, the number of articles retrieved (201) for full-article screening are shown in a box, and then they are screened a first time by methodologists, against a core set of inclusion criteria. Excluded articles (108) exit the diagram to the right. Continuing down the flow diagram, the remaining articles (93) are screened a second time, by clinical experts as well as methodologists, against the full set of inclusion criteria. Excluded articles (21) exit the diagram to the right and are listed in a box with specific reasons for exclusion. Finally, at the bottom of the diagram the number of included studies (72) are shown.

## Key Question Among individuals with asthma, what is the effectiveness of interventions to reduce or remove exposures to indoor inhalant allergens on asthma control, exacerbations, quality of life, and other relevant outcomes?

### Description of Included Studies

Thirty-eight studies assessed individual (single component) interventions, and 30 studies assessed multicomponent interventions. The following specific interventions were evaluated:

- Acaricide (i.e., house dust mite [HDM] pesticide applied to carpets, mattresses, furniture)
- Air purification (i.e., devices designed to filter room air)
- Carpet removal (i.e., removal of carpeting or area rugs from one or more rooms)
- High-efficiency particulate air-filtration (HEPA) vacuum (i.e., routine use of HEPA vacuum for cleaning carpeting or rugs of any type)
- Mattress covers (i.e., impermeable covers placed on mattresses)
- Mold removal (i.e., professional cleaning of mold-covered surfaces)
- Pest control (i.e., traps, poison, and/or professional services designed to control common house pests such as cockroaches and mice)
- Pet removal (i.e., confinement to specific rooms within a house, or complete removal of furry pets such as dogs and cats)
- Multicomponent interventions with more than one strategy for reducing one or more allergen exposures

Mattress covers were the most frequently studied intervention, assessed in 17 single-intervention studies and 19 multicomponent trials. Conversely, we found the smallest body of evidence for pet removal, which was examined in only three studies. Twenty-two studies enrolled patients 12 years of age and above, while 9 studies were limited to children under 12. Thirty-six studies included patients above and below the age of 12. Thirty-four studies were conducted in Europe, 24 were performed in the United States, and the remaining 10 were conducted in Canada, Australia, New Zealand, or Asian countries. Table 2 provides an overview of the distribution of the studies. Figure 3 highlights the distribution of study designs by populations and complexity of the interventions.

Table 2 Overview of interventional studies for reducing exposure to allergens

Intervention | Randomized Controlled Trials (number of studies, cumulative sample size, range of sample size) | Other Study Designs (number of studies, cumulative sample size) | Age Cohorts^*^ (number of studies in each cohort) | Country/Region
Acaricides (dust mite pesticide) | 6 n=229 (Range 26–62) | 1 nonrandomized trial n=59 | 3 adult 4 mixed | 6 Europe 1 Canada
Air purification | 9 n=311 (Range 10–119) | 0 | 4 adult 1 pediatric 4 mixed | 1 United States 7 Europe 1 New Zealand
Carpet removal | 0 | 0 | Not applicable | Not applicable
HEPA vacuums | 1 n=60 | 0 | 1 mixed | 1 Europe
Mattress covers | 17 n=2,287 (Range 20–1,122) | 0 | 9 adult 1 pediatric 6 mixed 1 not reported | 11 Europe 4 Asia 2 Australia
Mold removal | 0 | 0 | Not applicable | Not applicable
Pest control | 1 n=102 | 1 pre-post n=78 | 2 mixed | 2 United States
Pet removal | 0 | 1 nonrandomized trial (n=20) | 1 adult | 1 Asia
Other (1 study of bleach cleaning) | 1 n=97 | 0 | 1 mixed | 1 United States
Multicomponent | 25 n=4,338 (Range 23–937) | 3 pre-post (n=365) 2 nonrandomized controlled trials (n=204) | 5 adult 7 pediatric 18 mixed | 20 United States 9 Europe 1 Australia
Total | 60 | 4 nonrandomized trials 4 pre-post | 22 adult 9 pediatric 36 mixed 1 not reported | 24 United States 1 Canada 34 Europe 5 Asia 4 Australia/New Zealand

* Adult=all patients were ≥12 years old; Mixed=study included pediatric and adult patients; Pediatric=all patients were <12 years old

HEPA= high-efficiency particulate air-filtration

Figure 3 Number of included studies per study design and age group

RCT= Randomized controlled trial

Figure 3 is a bar graph that shows the number of studies by age category, study design, and whether the study used one intervention or a multicomponent intervention. On the left are six bars that represent the entire body of evidence in this review, including: 20 randomized controlled trials (RCTs) that include only adults or youths 12 years and older (named “Only Adults”); 2 non-RCTs with “Only Adults”; 30 RCTs with a mixed population of patients above and below age 12; 6 non-RCTs with a mixed population; 9 RCTs with only children under age 12; and no non-RCTs with only children. In the middle of the figure are six more bars, depicting the same type of data, but for studies that used a single intervention; for these studies, there were 15 RCTs and 2 non-RCTs with Only Adults; 17 RCTs and 1 non-RCT with mixed populations; and 2 RCTs and no non-RCTs with only children. Finally, the bars on the right describe the multicomponent intervention studies. There were 5 RCTs and no non-RCTs with Only Adults; 13 RCTs and 5 non-RCTs with mixed populations; and 7 RCTs and no non-RCTs with only children.

### Key Points

- The evidence that either single or multicomponent interventions intended to reduce allergen exposure improve asthma outcomes is limited by a lack of high quality studies. Overall strength of evidence (SOE) was either low, inconclusive, or no studies were available.
- No high or moderate strength evidence found improvement in clinical outcomes resulting from single component interventions.
- Overall, multicomponent interventions performed better than single interventions.
- Multicomponent strategies that included HEPA vacuums reduced exacerbations and improved quality of life (moderate SOE), while strategies that included mattress covers improved asthma symptoms (high SOE), and strategies that included pest control reduced exacerbations (moderate SOE).
- Mattress covers, when used without other interventions, did not affect asthma control (moderate SOE), exacerbations (moderate SOE), health care utilization (high SOE), pulmonary physiology (high SOE), quality of life (high SOE), or asthma symptoms (high SOE), despite reducing the allergen burden detected on mattress surfaces (moderate SOE).
- Qualitative comparative analysis affirmed the general lack of robust findings of improved outcome effects. No single allergen interventions were determined to be necessary or sufficient for effectiveness. Multicomponent bundles were characterized by substantial heterogeneity, and no conclusions about the effectiveness of specific combinations could be supported by the evidence.
- Important limitations of the evidence base include population heterogeneity (in terms of age and asthma severity), infrequent reporting of validated asthma outcome measures, poor data reporting, and variation in how interventions were implemented.
- Further research is needed examining indoor allergen reduction interventions in comparative studies with sufficient population sizes to detect clinically meaningful differences in relevant and validated asthma outcomes.

Table 3 summarizes the SOE for each intervention. Due to the heterogeneity of the included studies, we did not attempt to combine data from the studies quantitatively. Instead, we provide a narrative synthesis. Tables 4 through 10 address single component interventions, and Tables 11 and 12 address multicomponent interventions. Detailed evidence tables presenting information on the design of the studies, study populations, findings, and assessment of study limitations (risk of bias) are located in Appendix C.

Table 3 Allergen reduction interventions summary results and strength of evidence

Intervention (n=Studies) | Asthma Control | Exacerbations | Health Care Utilization | Absenteeism | Pulmonary Physiology | Quality of Life | Symptoms | Allergen Reduction
Acaricide only (n=7) | NA | NA | NA | NA | No effect (Moderate) | Inconclusive^*^ | Inconclusive^*^ | Inconclusive^*^
Acaricide multicomponent (n=6) | NA | Inconclusive^*^ | Inconclusive^*^ | NA | No effect (Moderate) | NA | No effect (High) | Improved (Low)
Air purification only (n=9) | Inconclusive^*^ | No effect (Low) | No effect (Low) | NA | No effect (Low) | Improved (Low) | Inconclusive^*^ | No effect (Low)
Air purification multicomponent (n=5) | No effect (Low) | No effect (High) | NA | Improved (Low) | Inconclusive^*^ | No effect (High) | Improved (Low) | Improved (Moderate)
Carpet removal only (n=0) | NA | NA | NA | NA | NA | NA | NA | NA
Carpet removal multicomponent (n=8) | NA | Inconclusive^*^ | Inconclusive^*^ | NA | Inconclusive^*^ | Inconclusive^*^ | Inconclusive^*^ | Improved (Moderate)
HEPA vacuum only (n=1) | NA | NA | NA | NA | Inconclusive^*^ | NA | NA | Inconclusive^*^
HEPA vacuum multicomponent (n=8) | Inconclusive^*^ | Improved (Moderate) | No effect (High) | Improved (Low) | Inconclusive^*^ | Improved (Moderate) | Improved (Low) | Improved (Moderate)
Mattress cover only (n=17) | No effect (Moderate) | No effect (Moderate) | No effect (High) | Improved (Low) | No effect (High) | No effect (High) | No effect (High) | Improved (Moderate)
Mattress cover multicomponent (n=19) | Inconclusive^*^ | No effect (High) | Inconclusive^*^ | Improved (Low) | No effect (High) | No effect (Moderate) | Improved (High) | Improved (Low)
Mold removal only (n=0) | NA | NA | NA | NA | NA | NA | NA | NA
Mold removal multicomponent (n=6) | NA | Inconclusive^*^ | Inconclusive^*^ | NA | Inconclusive^*^ | Inconclusive^*^ | Improved (Low) | Inconclusive^*^
Pest control only (n=2) | Inconclusive^*^ | Inconclusive^*^ | NA | Inconclusive^*^ | Inconclusive^*^ | NA | Improved (Low) | Inconclusive^*^
Pest control multicomponent (n=13) | Inconclusive^*^ | Improved (Moderate) | Inconclusive^*^ | Improved (Low) | Inconclusive^*^ | Improved (Low) | Improved (Low) | Improved (Low)
Pet removal only (n=1) | NA | Inconclusive^*^ | Inconclusive^*^ | NA | NA | NA | NA | NA
Pet removal multicomponent (n=2) | NA | NA | NA | NA | NA | NA | NA | NA

* Inconclusive due to insufficient evidence;

HEPA=high-efficiency particulate air-filtration; NA=not applicable

Table 4 Acaricide (dust mite pesticide) interventions summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)^**^
Acaricide vs. placebo | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. placebo | Exacerbations | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. placebo | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. placebo | Pulmonary physiology: spirometry | No effect: No reported differences between acaricide and placebo for FEV_1_, PEFR, or FVC measures. | 4 RCTs^26–29^ 1 non-RCT^30^ n=219 | Moderate (Imprecise)
Acaricide vs. placebo | Pulmonary physiology: airway hyper-responsiveness | Inconclusive: RCT found no difference between acaricide and placebo; non-RCT reported a statistically significant but not clinically significant improvement in PC_20_ following use of acaricide. | 1 RCT^25^ 1 non-RCT^30^ n=93 | Insufficient (Inconsistent, Imprecise) ^**^Substantial imprecision
Acaricide vs. placebo | Quality of Life | Inconclusive: Small RCT showed no between-group difference in quality of life; data shown graphically with no estimation of variability. | 1 RCT^29^ n=62 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Acaricide vs. placebo | Symptoms (secondary measure) | Inconclusive: Small RCT found improvements in both parent and physician ratings of child’s asthma severity, but no differences in frequency of wheezing. | 1 RCT^24^ n=35 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Acaricide vs. placebo | Allergen levels: Environmental measures (secondary measure) | Inconclusive: Small RCT^24^ showed decreased levels of HDM allergens in both groups, with a greater decrease in the acaricide group. Another small RCT^26^ showed no difference between groups for allergens in carpet or mattress, but found a reduction of allergens in other areas of the house. The remaining studies found no differences between groups. | 4 RCTs^24,26,27,29^ 1 non-RCT^30^ n=228 | Insufficient (Inconsistent, Imprecise)
Acaricide vs. other mite- avoidance interventions | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. other mite- avoidance interventions | Exacerbations | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. other mite- avoidance interventions | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. other mite- avoidance interventions | Pulmonary physiology | No effect: No reported differences between acaricide and other mite-avoidance interventions for FEV_1_, PEFR, or FVC measures. | 2 RCTs^28,29^ 1 non-RCT^30^ n=147 | Low (Study limitations, Imprecise)
Acaricide vs. other mite- avoidance interventions | Quality of life | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. other mite- avoidance interventions | Symptoms (secondary measure) | Not evaluable: Not reported in included studies. | NA | NA
Acaricide vs. other mite- avoidance interventions | Allergen levels (secondary measure) | Inconclusive: No studies showed between-group differences in allergen levels. Reported data did not allow assessment of precision. | 2 RCTs^28,29^ 1 non-RCT^30^ n=147 | Insufficient (Study limitations, Imprecise) ^**^Unable to determine effect from reported data

* Outcomes of Asthma control, Exacerbations, Health care utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

** Criteria for downgrading strength of evidence is described as Rationale; when these criteria are insufficient for understanding the final strength of evidence, additional explanation is provided.

Der p=dermatophagoides pteronyssinus allergen; FEV_1_=forced expiratory volume in one second; FVC=forced vital capacity; HDM=house dust mite; IgE=immunoglobulin E; NA=not available; PC_20_=provocative concentration 20; PEFR=peak expiratory flow rate; RCT=randomized controlled trial

Table 5 Air purification interventions summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)^**^
Air filtration/air purifier vs. control | Asthma control | Inconclusive: 1 RCT with low risk of bias showed no differences in ACQ scores. 1 RCT with high risk of bias showed an improvement in combined asthma outcomes following use of air cleaners. 1 RCT^35^ did not report differences in asthma scores between interventions. | 3 RCTs^35,37,40^ n=169 | Insufficient (Inconsistent, Imprecise) ^**^Unable to determine effect from reported data
Air filtration/air purifier vs. control | Exacerbations | No effect: Measures of ED visits and use of rescue medications did not differ between treatment conditions. | 3 RCTs^32,35,40^ n=167 | Low (Study limitations, Imprecise)
Air filtration/air purifier vs. control | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
Air filtration/air purifier vs. control | Pulmonary physiology | No effect: 5 RCTs showed no differences in spirometry measures. 1 other RCT^40^ showed improvements in evening peak flow, but in no other spirometry measures. 1 other RCT^34^ showed improvements in peak flow variation and airway hyper-responsiveness but not in FEV_1_. | 7 RCTs^32–35,37,38,40^ n=263 | Low (Inconsistent, Imprecise)
Air filtration/air purifier vs. control | Quality of life: mini-AQLQ | Improvement: 1 RCT^32^ found significant improvement in mini-AQLQ scores for active air cleaners compared with placebo (mean difference in change [SEM], active – placebo = 0.54 (0.28); p<0.05). | 1 RCT^32^ n=28 | Low (Study limitations, Unknown consistency)
Air filtration/air purifier vs. control | Quality of life: other measures | No effect: 2 RCTs showed no between-group differences in quality of life. | 2 RCTs^33,40^ n=155 | Moderate (Imprecise)
Air filtration/air purifier vs. control | Symptoms (secondary measure) | Inconclusive: Following intervention, 1 small RCT^36^ reported improvements in self-report asthma symptoms but provided no summary statistics. | 1 RCT^36^ n=18 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Air filtration/air purifier vs. control | Allergen levels (secondary measure) | No effect: 4 RCTs^33,34,37,40^ found no differences between treatment groups. 1 small RCT^35^ showed decreased levels of Der p during the active intervention compared with placebo. | 5 RCTs^33–35,37,40^ n=225 | Low (Imprecise)
Air filtration/air purifier vs. other mite avoidance interventions | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Air filtration/air purifier vs. other mite avoidance interventions | Exacerbations | Not evaluable: Not reported in included studies. | NA | NA
Air filtration/air purifier vs. other mite avoidance interventions | Healthcare utilization | Not evaluable: Not reported in included studies. | NA | NA
Air filtration/air purifier vs. other mite avoidance interventions | Pulmonary physiology | Inconclusive: 1 RCT showed no differences for FEV_1_, vital capacity, histamine PC_20_. Data were shown graphically for the 2 groups with no estimate of variability; analyses for between-group comparisons not reported. | 1 RCT^39^ n=30 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Air filtration/air purifier vs. other mite avoidance interventions | Quality of life | Not evaluable: Not reported in included studies. | NA | NA
Air filtration/air purifier vs. other mite avoidance interventions | Symptoms (secondary measure) | Not evaluable: Not reported in included studies. | NA | NA
Air filtration/air purifier vs. other mite avoidance interventions | Allergen levels (secondary measure) | Inconclusive: Between-groups analyses not reported. | 1 RCT^39^ n=30 | Insufficient (Unknown consistency, Imprecise) ^**^Unable to determine effect from reported data

* Outcomes of Asthma control, Exacerbations, Healthcare utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

** Criteria for downgrading strength of evidence is described as Rationale; when these criteria are insufficient for understanding the final strength of evidence, additional explanation is provided.

ACQ=asthma control questionnaire; AQLQ=asthma quality of life questionnaire; Der p=dermatophagoides pteronyssinus allergen; ED=emergency department; FEV_1_=forced expiratory volume in 1 second; HDM=house dust mite; NA=not available; PC_20_=provocative concentration causing a 20% drop in FEV_1_; RCT=randomized controlled trial; SEM=standard error of the mean

Table 6 HEPA vacuum interventions summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)^**^
HEPA vacuum vs. standard vacuum | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
HEPA vacuum vs. standard vacuum | Exacerbations | Not evaluable: Not reported in included studies. | NA | NA
HEPA vacuum vs. standard vacuum | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
HEPA vacuum vs. standard vacuum | Pulmonary physiology | Inconclusive: 1 RCT showed improvements in FEV_1_ and peak flow, but only p-values were reported for between-group comparisons. | 1 RCT^41^ n=60 | Insufficient (Unknown consistency, Imprecise) ^*^Substantial imprecision
HEPA vacuum vs. standard vacuum | Quality of life | Not evaluable: Not reported in included studies. | NA | NA
HEPA vacuum vs. standard vacuum | Symptoms (secondary measure) | Not evaluable: Not reported in included studies. | NA | NA
HEPA vacuum vs. standard vacuum | Allergen levels (secondary measure) | Inconclusive: Between-group comparisons not reported. Use of HEPA vacuum reduced allergen levels compared with baseline for some areas and allergens. | 1 RCT^41^ n=60 | Insufficient (Unknown consistency, Imprecise) ^**^Unable to determine effect from reported data

* Outcomes of Asthma control, Exacerbations, Healthcare utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

** Criteria for downgrading strength of evidence is described as Rationale; when these criteria are insufficient for understanding the final strength of evidence, additional explanation is provided.

FEV_1_=forced expiratory volume in 1 second; HEPA=high-efficiency particulate air-filtration; NA=not available; RCT=randomized controlled trial

Table 7 Mattress cover interventions summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)^**^
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Asthma control | No effect: No difference in ACQ scores in RCT of 126 adults and RCT of 284 mixed-population subjects. | 2 RCTs^42,43^ n=410 | Moderate (Imprecise)
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Exacerbations | No effect: No difference in composite measure of hospitalization and/or rescue medication use in RCT of 1,122 adults. No difference in frequency of asthma attacks in RCT of 55 adults. Significant reduction in composite measure of hospitalization or ED visit in 1 RCT of 284 mixed-population subjects. | 3 RCTs^42,47,48^ n=1,461 | Moderate (Inconsistent)
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Health care utilization: inhaled corticosteroid use | No effect: No difference for total dosage change in RCT of 126 adults. No difference for mean change in 28-day dose in RCT of 47 mixed-population subjects. Significantly greater reduction in mean daily dose in RCT of 60 mixed-population subjects. | 3 RCTs^43,46,50^ n=233 | Low (Inconsistent, Imprecise)
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Health care utilization: rescue medication use | No effect: No difference in 2 RCTs of 1,154 adults and 2 RCTs of 91 mixed-population subjects for beta agonist use or dose. No difference in use of undefined “rescue medication” in RCT of 30 adults. | 5 RCTs^44,46,48,49,51^ n=1,275 | High
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Health care utilization and costs: work absenteeism | Decreased workdays: Significant decrease in missed days of work in RCT of 1,122 adults, but difference may not be meaningful: Mean difference: −0.15 days per month (95% CI: −0.29 to −0.02). | 1 RCT^48^ n=1,122 | Low (Unknown consistency, Imprecise)
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Pulmonary physiology | No effect: No difference in morning or evening peak flow for 8 RCTs of 1,535 adults and 4 RCTs of 158 mixed-population subjects. Significant improvement reported in RCT of 25 adults. | 13 RCTs^43–55^ n=1,744 | High
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Quality of life | No effect: No difference in 5 RCTs of 1,365 adults and 1 RCT of 284 mixed-population subjects; 2 used the Modified AQLQ-Marks; 1 used mini-AQLQ; 1 used St George’s Respiratory Questionnaire; 1 used PACQLQ; 1 used Quality of Life for Respiratory Illness Questionnaire | 6 RCTs^42–44,47–49^ n=1,649 | High
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Symptoms (secondary measure) | No effect: No difference in 7 RCTs (n=1,470; 4 in adults and 3 in mixed populations.) Significant improvement in RCT of 25 adults. Studies used similar but not identical sets of composite scores, ranging from 3 to 8 discrete items (e.g., cough, wheeze) | 8 RCTs^43,44,46,48–52^ n=1,473 | High
Impermeable covers on mattress, pillow, and/or duvet vs. placebo covers or no intervention | Allergen levels (secondary measure) | Allergen reduction: Significant reduction in Der p and/or Der f allergen in 6 RCTs of 1,387 adults and 3 RCTs of 375 mixed-population subjects. No difference in 2 RCTs of 141 adults. | 11 RCTs^42–49,51,52,55^ n=1,928 | Moderate (Inconsistent)
Feather-filled pillow and quilt vs. impermeable cover on mattress, pillow, and quilt | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Feather-filled pillow and quilt vs. impermeable cover on mattress, pillow, and quilt | Exacerbations | Not evaluable: Not reported in included studies. | NA | NA
Feather-filled pillow and quilt vs. impermeable cover on mattress, pillow, and quilt | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
Feather-filled pillow and quilt vs. impermeable cover on mattress, pillow, and quilt | Pulmonary physiology | Not evaluable: Not reported in included studies. | NA | NA
Feather-filled pillow and quilt vs. impermeable cover on mattress, pillow, and quilt | Quality of life | Inconclusive: No difference for overall quality of life: Adjusted difference effect: 0.04 (95% CI: −0.27 to 0.35; p=0.80). | 1 RCT^56^ n=197 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Feather-filled pillow and quilt vs. impermeable cover on mattress, pillow, and quilt | Symptoms (secondary measure) | Inconclusive: No difference for frequent wheeze, speech-limiting wheeze, or sleep disturbance caused by wheeze. | 1 RCT^56^ n=197 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Feather-filled pillow and quilt vs. impermeable cover on mattress, pillow, and quilt | Allergen levels (secondary measure) | Inconclusive: No difference for Der p 1 allergen: Median exposure: 16.0 pg-m3 (IQR: 1.0 to 54.1) vs. 28.0 pg-m3 (IQR: 1.0 to 66.8, p=0.30). | 1 RCT^56^ n=197 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Impermeable pillow vs. placebo pillow | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Impermeable pillow vs. placebo pillow | Exacerbations | Inconclusive: No difference in number of asthma attacks (data reported in graph and cannot be evaluated). | 1 RCT^57^ n=20 | Insufficient (Unknown consistency, Imprecise, Reporting Bias Detected)
Impermeable pillow vs. placebo pillow | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
Impermeable pillow vs. placebo pillow | Pulmonary physiology | Not evaluable: Not reported in included studies. | NA | NA
Impermeable pillow vs. placebo pillow | Quality of life | Not evaluable: Not reported in included studies. | NA | NA
Impermeable pillow vs. placebo pillow | Symptoms (secondary measure) | Not evaluable: Not reported in included studies. | NA | NA
Impermeable pillow vs. placebo pillow | Allergen levels (secondary measure) | Inconclusive: No difference in IgE levels for HDM (data reported in graph and cannot be evaluated). | 1 RCT^57^ n=20 | Insufficient (Unknown consistency, Imprecise, Reporting Bias Detected)
Cotton bed covers boiled and exposed to 3 hours of sunlight every 2 weeks vs. standard laundering | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Cotton bed covers boiled and exposed to 3 hours of sunlight every 2 weeks vs. standard laundering | Exacerbations | Inconclusive: No difference in asthma attacks. | 1 RCT^58^ n=42 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Cotton bed covers boiled and exposed to 3 hours of sunlight every 2 weeks vs. standard laundering | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
Cotton bed covers boiled and exposed to 3 hours of sunlight every 2 weeks vs. standard laundering | Pulmonary physiology | Inconclusive: No difference for morning or evening peak flow. | 1 RCT^58^ n=42 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Cotton bed covers boiled and exposed to 3 hours of sunlight every 2 weeks vs. standard laundering | Quality of life | Not evaluable: Not reported in included studies. | NA | NA
Cotton bed covers boiled and exposed to 3 hours of sunlight every 2 weeks vs. standard laundering | Symptoms (secondary measure) | Inconclusive: No difference for frequency of cough, wheeze, or sputum. Significant reduction in frequency of dyspnea. | 1 RCT^58^ n=42 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Cotton bed covers boiled and exposed to 3 hours of sunlight every 2 weeks vs. standard laundering | Allergen levels (secondary measure) | Inconclusive: No difference between groups. | 1 RCT^58^ n=42 | Insufficient (Study limitations, Unknown consistency, Imprecise)

* Outcomes of Asthma control, Exacerbations, Healthcare utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

** Criteria for downgrading strength of evidence is described as Rationale; when these criteria are insufficient for understanding the final strength of evidence, additional explanation is provided.

ACQ=asthma control questionnaire; AQLQ= asthma quality of life questionnaire; CI=confidence interval; Der f=dermatophagoides farina allergen; Der p=dermatophagoides pteronyssinus allergen; HDM=house dust mite; IgE=immunoglobulin E; IQR=interquartile range; NA=not available; PACQLQ= pediatric asthma caregivers asthma quality of life questionnaire; pg-m3=phosphoglucomutase 3 gene; RCT=randomized controlled trial

Table 8 Pest control interventions summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)^**^
Pest reduction interventions pre-and post-treatment | Asthma control | Inconclusive: ACT score did not improve significantly in 1 RCT. | 1 RCT^59^ n=102 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Pest reduction interventions pre-and post-treatment | Exacerbations | Inconclusive: ED or unscheduled clinic visits were significantly reduced after use of insecticide in 1 RCT, but hospitalizations did not improve; 1 pre-post study found no change in rates of exacerbations. | 1 RCT^59^ 1 pre-post study^60^ n=180 | Insufficient (Inconsistent, Imprecise) ^**^Substantial imprecision
Pest reduction interventions pre-and post-treatment | Health care utilization | Inconclusive: Patients sensitized to cockroach allergen missed significantly fewer school days after use of insecticide. | 1 RCT^59^ n=102 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Pest reduction interventions pre-and post-treatment | Pulmonary physiology | Inconclusive: FEV_1_ improved significantly for patients after use of insecticide, but improvement was not significant for a subset of patients sensitized to cockroach allergen. | 1 RCT^59^ n=102 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Pest reduction interventions pre-and post-treatment | Quality of life | Not evaluable: Not reported in included studies. | NA | NA
Pest reduction interventions pre-and post-treatment | Symptoms (secondary measure) | Improvement: Significant improvement in respiratory symptoms in RCT and in pre-post study. | 1 RCT^59^ 1 pre-post study^60^ n=180 | Low (Imprecise)
Pest reduction interventions pre-and post-treatment | Allergen levels (secondary measure) | Inconclusive: All allergens were reported to decrease from baseline, with no statistical analysis or description of statistical significance. | 1 pre-post study^60^ n=78 | Insufficient (Unknown consistency, Imprecise) ^**^Pre-post study

* Outcomes of Asthma control, Exacerbations, Healthcare utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

** Criteria for downgrading strength of evidence is described as Rationale; when these criteria are insufficient for understanding the final strength of evidence, additional explanation is provided.

ACT=asthma control test; ED=emergency department; FEV_1_= forced expiratory volume in one second; NA=not available; RCT=randomized controlled trial

Table 9 Pet removal interventions summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)^**^
Pet removal vs. keeping pets | Asthma control | Not evaluable: Not reported in included study. | NA | NA
Pet removal vs. keeping pets | Exacerbations/hospitalizations | Inconclusive: No patients in the removal group experienced exacerbations or hospitalizations. 2 patients who kept pets experienced either an exacerbation or hospitalization. No statistics presented in study. | 1 non-RCT^61^ n=20 | Insufficient (Unknown consistency, Imprecise) ^**^Non-RCT
Pet removal vs. keeping pets | Health care utilization | Inconclusive: Both use of inhaled corticosteroids and followup visits to the medical office were statistically significantly reduced in the pet-removal group. | 1 non-RCT^61^ n=20 | Insufficient (Unknown consistency) ^**^Non-RCT
Pet removal vs. keeping pets | Pulmonary physiology | Not evaluable: Not reported in included study. | NA | NA
Pet removal vs. keeping pets | Quality of life | Not evaluable: Not reported in included study. | NA | NA
Pet removal vs. keeping pets | Symptoms (secondary measure) | Not evaluable: Not reported in included study. | NA | NA
Pet removal vs. keeping pets | Allergen levels (secondary measure) | Not evaluable: Not reported in included study. | NA | NA

* Outcomes of Asthma control, Exacerbations, Healthcare utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

** Criteria for downgrading strength of evidence is described as Rationale; when these criteria are insufficient for understanding the final strength of evidence, additional explanation is provided.

NA=not available; non-RCT=non-randomized controlled trial

Table 10 Cleaning products intervention summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)
Cleaning products vs. no cleaning products | Asthma control | Inconclusive: Not possible to determine effectiveness of hypothesized effective intervention of sodium hypochlorite. | 1 RCT^62^ 97 families | Insufficient (Study limitations, Unknown consistency, Imprecise)
Cleaning products vs. no cleaning products | Exacerbations | Inconclusive: Overall rates of exacerbations described as low for all groups (data not shown). | 1 RCT^62^ 97 families | Insufficient (Study limitations, Unknown consistency, Imprecise)
Cleaning products vs. no cleaning products | Health care utilization | Not evaluable: Not reported in included studies. | NA | NA
Cleaning products vs. no cleaning products | Pulmonary physiology | Not evaluable: Not reported in included studies. | NA | NA
Cleaning products vs. no cleaning products | Quality of life | Inconclusive: Main outcome of quality of life was improved in all groups; authors note the possibility of placebo effect due to keeping diaries in-group with no cleaning products. | 1 RCT^62^ 97 families | Insufficient (Study limitations, Unknown consistency, Imprecise)
Cleaning products vs. no cleaning products | Symptoms (secondary measure) | Not evaluable: Not reported in included studies. | NA | NA
Cleaning products vs. no cleaning products | Allergen levels (secondary measure) | Inconclusive: Levels of all dust allergens did not vary statistically as a function of treatment group. Comparative data not shown for cleaning compared with no cleaning in participants with asthma. | 1 RCT^62^ 97 families | Insufficient (Study limitations, Unknown consistency, Imprecise)

* Outcomes of Asthma control, Exacerbations, Healthcare utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

NA=not available; RCT=randomized controlled trial

Table 11 Multicomponent indoor allergen reduction interventions by study

Study | Acaricide (Dust Mite Pesticide) | Air Purification | Carpet Removal^*^ | HEPA Vacuum | Mattress Covers | Mold Removal | Pest Control | Pet Removal^*^ | Laundering Linens | Cleaning Supplies Provided | CHW Education/Instruction | Other
Matsui et al. 2017^63^ | | ✓ | | | ✓ | | ✓
DiMango et al. 2016^64^ | | ✓ | | ✓ | ✓ | | | | | ✓
Shani et al. 2015^90,**^ | | | | | ✓ | | ✓ | | | ✓ | ✓
Breysse et al. 2014^88,**^ | | | ✓ | | | ✓ | | | | | | Weatherization
Turcotte et al. 2014^91,**^ | | | | ✓ | | | ✓ | | | ✓ | ✓ | Professional cleaning
Sweet et al. 2013^92,**^ | | | | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓ | Moisture control
El-Ghitany et al. 2012^87^ | ✓ | | ✓ | | ✓ | | | ✓ | ✓ | | | Ventilation
Takaro et al. 2011^89,**^ | | ✓ | | | | ✓ | | | | | | Ventilation
Bryant-Stephens et al. 2009^69^ | | | ✓ | | ✓ | | ✓ | | | ✓ | ✓
Krieger et al. 2009^68^ | | | | ✓ | | | | | | ✓ | ✓
Bryant-Stephens et al. 2008^70^ | | | ✓ | | ✓ | | ✓ | | | ✓ | ✓
Parker et al. 2008^65^ | | | | ✓ | ✓ | | ✓ | | | ✓ | ✓
Burr et al. 2007^82^ | | | | | | ✓ | | | | | | Positive ventilation fan
Kercsmar et al. 2006^83^ | | | | | | ✓ | | | | | | Moisture control
Williams et al. 2006^71^ | | | ✓ | | ✓ | ✓ | ✓ | ✓ | | | ✓ | Professional cleaning
Eggleston et al. 2005^78^ | | ✓ | | | ✓ | | ✓ | | | | ✓
Krieger et al. 2005^66^ | | | | ✓ | | | ✓ | | | ✓ | ✓
Morgan et al. 2004^67^ | | ✓ | | ✓ | ✓ | | ✓
Carter et al. 2001^79^ | | | | | ✓ | | ✓ | | ✓
Htut et al. 2001^84^ | | | | | | | | | ✓ | | | Ventilation; steam heating of mattress, duvet; new pillows
Warner et al. 2000^81^ | | | | ✓ | | | | | | | | House-wide ventilation system
Cloosterman et al. 1999^74^ | ✓ | | | | ✓
Evans et al. 1999^86^ | | | | | ✓ | | ✓ | | | | ✓
Shapiro et al. 1999^75^ | ✓ | | | | ✓ | | | | ✓
Hayden et al. 1997^73^ | ✓ | | ✓ | | ✓ | | | | ✓
Carswell et al. 1996^76^ | ✓ | | | | ✓ | | | | ✓
Marks et al. 1994^77^ | ✓ | | | | ✓
Walshaw et al. 1986^72^ | | | ✓ | | ✓ | | | | | | | Feather-based bedding replaced
Korsgaard et al. 1983^80^ | | | ✓ | | | | | | ✓ | | | Mattress vacuuming; pillows and quilts replaced; ventilation; clothes dried outdoors
Burr et al. 1980^85^ | | | | | | | | | ✓ | | | Mattress vacuuming; quilts removed; feather pillows replaced
Total | 6 | 5 | 8 | 8 | 19 | 6 | 13 | 2 | 8 | 9 | 11

* Applied to some but not all study participants;

** Not a randomized controlled trial;

CHW= community health worker; HEPA= high-efficiency particulate air-filtration

Table 12 Multicomponent interventions summary and strength of evidence

Comparison | Outcome^*^ | Conclusion | Study Design and Sample Size | Strength of Evidence (Rationale)^**^
Acaricide (dust mite pesticide) + other interventions vs. placebo | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Acaricide (dust mite pesticide) + other interventions vs. placebo | Exacerbations | Inconclusive: No difference in ED visits or hospitalizations in RCT of 44 mixed-population subjects. Significant reduction in hospitalizations in intervention group in RCT of 160 mixed-population subjects; no between-group comparison. | 2 RCTs^75,87^ n=204 | Insufficient (Inconsistent, Imprecise) ^**^Substantial imprecision
Acaricide (dust mite pesticide) + other interventions vs. placebo | Healthcare utilization | Inconclusive: Significantly less use of bronchodilator or any asthma medication in RCT of 70 children. | 1 RCT^76^ n=70 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Acaricide (dust mite pesticide) + other interventions vs. placebo | Pulmonary physiology: peak flow | No effect: No difference in peak flow in 2 RCTs of 192 adults and RCT of 70 children. Improved peak flow reported in RCT of 23 mixed-population subjects. Improved peak flow in intervention group in RCT of 160 mixed-population subjects; no between-group comparison. | 5 RCTs^73,74,76,77,87^ n=445 | Moderate (Inconsistent)
Acaricide (dust mite pesticide) + other interventions vs. placebo | Pulmonary physiology: FEV_1_ | No effect: No difference in FEV_1_ in 2 RCTs of 192 adults and 2 RCTs of 67 mixed-population subjects. Significant increase in FEV_1_ reported in RCT of 70 children. Significant increase in intervention group in RCT of 160 mixed-population subjects; no between-group comparison. | 6 RCTs^73–77,87^ n=489 | Moderate (Inconsistent)
Acaricide (dust mite pesticide) + other interventions vs. placebo | Quality of life | Not evaluable: Not reported in included studies. | NA | NA
Acaricide (dust mite pesticide) + other interventions vs. placebo | Symptoms (secondary measure) | No effect: No difference in frequency of symptoms in 2 RCTs in 192 adults, RCT in 44 mixed-population subjects, and RCT in 70 children. | 4 RCTs^74–77^ n=306 | High
Acaricide (dust mite pesticide) + other interventions vs. placebo | Allergen levels (secondary measure) | Reduced allergen: Significant reduction in HDM allergen found in RCT of 157 adults and RCT of 70 children. Significant reduction in intervention group in RCT of 160 mixed- population subjects; no between-group comparison. No difference in allergen levels in RCT of 35 adults and RCT of 44 mixed- population subjects. | 5 RCTs^74–77,87^ n=466 | Low (Inconsistent, Imprecise)
Air purification + other interventions vs. no intervention | Asthma control | No effect: No difference in ACT or childhood ACT score in RCT of 247 mixed-population subjects. | 1 RCT^64^ n=247 | Low (Unknown consistency, Imprecise)
Air purification + other interventions vs. no intervention | Exacerbations | No effect: No difference in hospitalizations in 2 RCTs of 1,037 children and 1 RCT of 361 mixed-population subjects. No difference in ED visits in RCT of 937 children and RCT of 361 mixed-population subjects. No difference in “exacerbations” reported in RCT of 247 mixed-population subjects. | 4 RCTs^63,64,67,78^ n=1,645 | High
Air purification + other interventions vs. no intervention | Health care utilization: acute care visits | Inconclusive: No difference in acute care visits (not defined) in RCT of 100 children. | 1 RCT^78^ n=100 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Air purification + other interventions vs. no intervention | Health care utilization and costs: school absenteeism | Improvement: Significantly fewer days of missed school reported in RCT of 937 children. | 1 RCT^67^ n=937 | Low (Unknown consistency, Imprecise)
Air purification + other interventions vs. no intervention | Pulmonary physiology | Inconclusive: No difference in FEV_1_ % predicted in RCT of 361 mixed-population subjects. | 1 RCT^63^ n=361 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Air purification + other interventions vs. no intervention | Quality of life | No effect: No difference in mini-AQLQ scores in RCT of 100 children and RCT of 247 mixed-population subjects. | 2 RCTs^64,78^ n=347 | High
Air purification + other interventions vs. no intervention | Symptoms (secondary measure) | Improved symptoms: Significant reduction in symptoms in 2 RCTs of 1,037 children. No difference in 2 RCTs of 608 mixed-population subjects. | 4 RCTs^63,64,67,78^ n=1,645 | Low (Inconsistent, Imprecise)
Air purification + other interventions vs. no intervention | Allergen levels (secondary measure) | Allergen reduction: Significant reduction for HDM, cockroach, cat, dog, and mouse allergen in RCT of 247 mixed-population subjects. Significant reduction in HDM, cockroach, and cat allergen in RCT of 937 children; no difference in dog allergen. Significant reduction in mouse allergen in RCT of 361 mixed-population subjects. No difference in allergens in RCT of 100 children. | 4 RCTs^63,64,67,78^ n=1,645 | Moderate (Inconsistent)
Carpet removal + other interventions vs. placebo or no intervention | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Carpet removal + other interventions vs. placebo or no intervention | Exacerbations | Inconclusive: No difference in ED visits or hospitalizations in 2 RCTs of 545 mixed- population subjects. Significant reduction in hospitalizations in intervention group in RCT of 160 mixed-population subjects; no between-group comparison. | 3 RCTs^69,70,87^ n=705 | Insufficient (Study limitations, Inconsistent, Imprecise)
Carpet removal + other interventions vs. placebo or no intervention | Health care utilization | Inconclusive: Significant reduction in use of inhaled steroids in intervention group in RCT of 50 adults; no between-group comparison. Significant reduction in number of daytime terbutaline puffs in RCT of 46 adults; no difference in nighttime puffs or overall use. | 2 RCTs^72,80^ n=96 | Insufficient (Study limitations, Imprecise) ^**^Substantial imprecision
Carpet removal + other interventions vs. placebo or no intervention | Pulmonary physiology | Inconclusive: Improved peak flow in intervention group in RCT of 50 adults and RCT of 160 mixed-population subjects; no between-group comparison. No difference in RCT of 46 adults. Significant improvement in RCT in 23 mixed-population subjects. | 4 RCTs^72,73,80,87^ n=279 | Insufficient (Inconsistent, Imprecise) ^**^Substantial imprecision
Carpet removal + other interventions vs. placebo or no intervention | Quality of life | Inconclusive: Significant improvement in PACQLQ scores in nonrandomized trial of 102 mixed-population subjects. | 1 non-RCT^88^ n=102 | Insufficient (Unknown consistency, Imprecise) ^**^Non-RCT
Carpet removal + other interventions vs. placebo or no intervention | Symptoms (secondary measure) | Inconclusive: No difference in symptoms in RCT of 50 adults and 2 RCTs of 545 mixed- population subjects. Significant reduction in symptoms in RCT of 161 children. Significant reduction in daytime scores, no difference in nighttime scores in RCT of 46 adults. | 5 RCTs^69–72,80^ n=802 | Insufficient (Study limitations, Inconsistent, Imprecise)
Carpet removal + other interventions vs. placebo or no intervention | Allergen levels (secondary measure) | Allergen reduction: Significant reduction in HDM allergen levels in 2 RCTs in 96 adults and RCT in 161 children. Significant reduction in intervention group in RCT of 160 mixed-population subjects; no between-group comparison. | 4 RCTs^71,72,80,87^ n=412 | Moderate (Study limitations)
HEPA vacuum + other interventions vs. placebo or no intervention | Asthma control | Inconclusive: No difference in ACT or childhood ACT scores in RCT of 247 mixed-population subjects. | 1 RCT^64^ n=247 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
HEPA vacuum + other interventions vs. placebo or no intervention | Exacerbations: composite measure based on level of care | Reduction: Significant improvement in composite measure of hospitalization, ED visits, and acute care clinic visits in 3 RCTs of children. | 3 RCTs^65–67^ n=1,509 | Moderate (Study limitations)
HEPA vacuum + other interventions vs. placebo or no intervention | Exacerbations: unspecified | No effect: No difference in undefined “exacerbations” or “asthma attacks” in 2 RCTs of mixed-population subjects. | 2 RCTs^64,68^ n=556 | Moderate (Imprecise)
HEPA vacuum + other interventions vs. placebo or no intervention | Health care utilization: medication use | No effect: No difference in use of rescue inhaler or beta agonists in 3 RCTs of mixed-population subjects. | 3 RCTs^64,66,68^ n=830 | High
HEPA vacuum + other interventions vs. placebo or no intervention | Health care utilization and costs: school absenteeism | No effect: No difference in missed school days in 2 RCTs (n=583). Significant reduction in 1 RCT (n=937). | 3 RCTs^66–68^ n=1,520 | Low (Inconsistent, Imprecise)
HEPA vacuum + other interventions vs. placebo or no intervention | Health care utilization and costs: work absenteeism | No effect: No difference in missed workdays. | 2 RCTs^66,68^ n=583 | Moderate (Study limitations)
HEPA vacuum + other interventions vs. placebo or no intervention | Health care utilization and costs: missed activities | Reduction: Fewer days of missed activities in RCT of 937 children and RCT of 274 mixed-population subjects. No difference in RCT of 309 mixed-population subjects. | 3 RCTs^66–68^ n=1,520 | Low (Inconsistent, imprecise)
HEPA vacuum + other interventions vs. placebo or no intervention | Pulmonary physiology: peak flow | Inconclusive: No difference in RCT of mixed-population subjects | 1 RCT^81^ n=40 | Insufficient (Study limitations, Unknown consistency, Imprecise)
HEPA vacuum + other interventions vs. placebo or no intervention | Pulmonary physiology: FEV_1_ | Inconclusive: No difference in RCT of mixed-population subjects. | 1 RCT^64^ n=247 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
HEPA vacuum + other interventions vs. placebo or no intervention | Quality of life: PACQLQ | Improvement: PACQLQ score improved significantly in 2 RCTs. | 2 RCTs^66,68^ n=583 | Moderate (Study limitations)
HEPA vacuum + other interventions vs. placebo or no intervention | Quality of life: mini-AQLQ | Inconclusive: No difference in mini-AQLQ scores in RCT of mixed-population subjects. | 1 RCT^64^ n=247 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
HEPA vacuum + other interventions vs. placebo or no intervention | Quality of life: CHSA | Inconclusive: Significant improvement in CHSA scores in pre-post study of 170 mixed-population subjects. | 1 pre-post^91^ n=170 | Insufficient (Unknown consistency, Imprecise) ^**^Non-RCT
HEPA vacuum + other interventions vs. placebo or no intervention | Symptoms: children (secondary measure) | Improved symptoms: Significant decrease in symptom days in 2 RCTs (n=1,235). No difference in symptom days in 1 RCT (n=274). | 3 RCTs^65–67^ n=1,509 | Low (Study limitations, Inconsistent)
HEPA vacuum + other interventions vs. placebo or no intervention | Symptoms: mixed populations (secondary measure) | No effect: No difference in 2 RCTs (n=287) in frequency of symptoms. Significant reduction in symptom days in 1 RCT (n=309). | 3 RCTs^64,68,81^ n=596 | Moderate (Inconsistent)
HEPA vacuum + other interventions vs. placebo or no intervention | Allergen levels: house dust mites (secondary measure) | Inconclusive: 3 RCTs did not specify Der p or Der f; 1 found significant reduction in allergen levels, 1 found no difference, and 1 found significant reduction in both intervention and control but had no comparison. A fourth RCT found reduced Der f but not Der p. | 4 RCTs^64,65,67,81^ n=1,522 | Insufficient (Study limitations, Inconsistent, Imprecise)
HEPA vacuum + other interventions vs. placebo or no intervention | Allergen levels: cats and dogs (secondary measure) | Inconclusive: 1 RCT found significant reduction in cat levels but not dog; 1 RCT found significant reduction in dog but not cat; 1 RCT found significant reductions in cat and dog in intervention group, but had no between-group comparison. | 3 RCTs^64,65,67^ n=1,195 | Insufficient (Inconsistent, Imprecise) ^**^Substantial inconsistency
HEPA vacuum + other interventions vs. placebo or no intervention | Allergen levels: cockroach (secondary measure) | Reduction: 1 RCT found significant reduction in cockroach levels; 1 RCT found significant reduction in intervention group but had no between-group comparison. | 2 RCTs^64,67^ n=1,184 | Moderate (Imprecise)
Mattress covers + other interventions vs. placebo or no intervention | Asthma control | Inconclusive: No difference in ACT or childhood ACT in 1 RCT (n=247). | 1 RCT^64^ n=247 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Mattress covers + other interventions vs. placebo or no intervention | Exacerbations: ED visits | No effect: No difference in 3 RCTs (n=906). | 3 RCTs^63,69,70^ n=545 | Low (Study limitations, Imprecise)
Mattress covers + other interventions vs. placebo or no intervention | Exacerbations: hospitalization | No effect: No difference in 6 RCTs (n=2,976). | 6 RCTs^63,67,69,70,78,86^ n=2,976 | High
Mattress covers + other interventions vs. placebo or no intervention | Exacerbations: unscheduled care including ED, hospital, outpatient | Inconclusive: No difference in 3 RCTs (n=1,181) on composite measure of unscheduled care; significant reduction in 2 RCTs (n=1,235). | 5 RCTs^65,67,75,79,86^ n=2,416 | Insufficient (Inconsistent, Imprecise) ^**^Substantial inconsistency
Mattress covers + other interventions vs. placebo or no intervention | Health care utilization: acute care visits | No effect: No difference in 3 RCTs (n=1,318) of unscheduled acute care visits. | 3 RCTs^67,70,78^ n=1,318 | Moderate (Study limitations)
Mattress covers + other interventions vs. placebo or no intervention | Health care utilization: medication use | Inconclusive: Reduced use of any asthma medication in 1 RCT (n=70); no difference in use of rescue inhaler in 1 RCT (n=247). | 2 RCTs^64,76^ n=317 | Insufficient (Inconsistent, Imprecise) ^**^Substantial imprecision
Mattress covers + other interventions vs. placebo or no intervention | Health care utilization and costs: school absenteeism | Reduction: Significantly fewer missed school days in 1 RCT (n=937). | 1 RCT^67^ n=937 | Low (Unknown consistency, Imprecise)
Mattress covers + other interventions vs. placebo or no intervention | Health care utilization and costs: missed activities | Reduction: Fewer days of missed activities in 1 RCT (n=937). | 1 RCT^67^ n=937 | Low (Unknown consistency, Imprecise)
Mattress covers + other interventions vs. placebo or no intervention | Pulmonary physiology: peak flow | Inconclusive: Significant improvement in peak flow in 2 RCTs (n=321); no difference in 3 RCTs (n=262). | 5 RCTs^65,73,74,76,77^ n=583 | Insufficient (Inconsistent, Imprecise) ^**^Substantial inconsistency
Mattress covers + other interventions vs. placebo or no intervention | Pulmonary physiology: FEV_1_ | No effect: No difference in 7 RCTs (n=1,804); significant improvement in 1 RCT (n=70). | 8 RCTs^63,64,67,73–77^ n=1,874 | High
Mattress covers + other interventions vs. placebo or no intervention | Quality of life | No effect: No difference in 1 RCT using AQLQ; no difference in 2 RCTs using unspecified quality-of-life scales. | 3 RCTs^64,75,78^ n=144 | Moderate (Study limitations)
Mattress covers + other interventions vs. placebo or no intervention | Symptoms: composite symptom score (secondary measure) | No effect: No difference in 4 RCTs that used different sets of symptoms to derive composite scores (n=483). | 4 RCTs^64,74,75,77^ n=483 | High
Mattress covers + other interventions vs. placebo or no intervention | Symptoms: symptom days (secondary measure) | Reduction: Significantly fewer days reported with symptoms in 4 RCTs (n=2,368); no effect reported in 1 RCT. | 5 RCTs^63,65,67,78,86^ n=2,729 | High
Mattress covers + other interventions vs. placebo or no intervention | Symptoms: cough and wheeze (secondary measure) | No effect: No change in frequency of cough in 3 RCTs; reduced cough reported in 1 RCT; no change in frequency of wheeze reported in 4 RCTs; reduced wheeze reported in 1 RCT. | 5 RCTs^65,67,69,70,76^ n=1,850 | Low (Study limitations, Inconsistent)
Mattress covers + other interventions vs. placebo or no intervention | Allergen reduction (secondary measure) | Reduction: Significant reduction in Der allergen reported in 4 RCTs (n=1,305); no effect reported in 4 RCTs (n=477). | 8 RCTs^65,67,71,72,74,75,77,78^ n=1,782 | Low (Inconsistent, Imprecise)
Mold removal + other interventions vs. placebo or no intervention | Asthma control | Not evaluable: Not reported in included studies. | NA | NA
Mold removal + other interventions vs. placebo or no intervention | Exacerbations | Inconclusive: No difference in number of urgent care or ED visits in RCT of 62 mixed-population subjects. | 1 RCT^83^ n=62 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Mold removal + other interventions vs. placebo or no intervention | Health care utilization | Inconclusive: Reduced need for relief medication in RCT of 232 mixed-population subjects. | 1 RCT^82^ n=232 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Mold removal + other interventions vs. placebo or no intervention | Pulmonary physiology | Inconclusive: No difference in peak flow variability in RCT of 232 mixed-population subjects. | 1 RCT^82^ n=232 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Mold removal + other interventions vs. placebo or no intervention | Quality of life | Inconclusive: No difference in mean CHSA scores in RCT of 62 mixed-population subjects. | 1 RCT^83^ n=62 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Mold removal + other interventions vs. placebo or no intervention | Symptoms (secondary measure) | Improved symptoms: Significant decrease in symptoms in RCT of 161 children and RCT of 62 mixed-population subjects. | 2 RCTs^71,83^ n=223 | Low (Study limitations, Imprecise)
Mold removal + other interventions vs. placebo or no intervention | Allergen levels (secondary measure) | Inconclusive: Significant reduction in mold scores in RCT of 62 mixed-population subjects. | 1 RCT^83^ n=62 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Pest control + other interventions vs. placebo or no intervention | Asthma control | Inconclusive: No difference in ACT or childhood ACT scores in pre-post study of 80 mixed-population subjects. | 1 pre-post^90^ n=80 | Insufficient (Unknown consistency, Imprecise) ^**^Pre-post study
Pest control + other interventions vs. placebo or no intervention | Exacerbations: Composite measure of urgent care | Reduction: Significant improvement in composite measure of hospitalization, ED visits, and acute care clinic visits in 3 RCTs of 1,509 children and RCT of 104 mixed-population subjects. | 4 RCTs^65–67,79^ n=1,613 | Moderate (Study limitations)
Pest control + other interventions vs. placebo or no intervention | Exacerbations: Hospitalization | No effect: No difference in hospitalizations in 3 RCTs of 2,070 children and 2 RCTs of 625 mixed-population subjects. No difference in inpatient days in RCT of 281 mixed-population subjects. | 6 RCTs^63,67,69,70,78,86^ n=2,976 | High
Pest control + other interventions vs. placebo or no intervention | Exacerbations: ED visits | No effect: No difference in ED visits in 1 RCT of 937 children and 3 RCTs of 906 mixed-population subjects. | 4 RCTs^63,67,69,70^ n=1,843 | Moderate (Study limitations)
Pest control + other interventions vs. placebo or no intervention | Health care utilization: acute care clinic visits | No effect: No difference in clinic visits for acute care in 3 RCTs of 2,070 children. | 3 RCTs^67,78,86^ n=2,070 | High
Pest control + other interventions vs. placebo or no intervention | Health care utilization: medication use | Inconclusive: No difference in use of beta-agonist or controller medications in RCT of 274 children. | 1 RCT^66^ n=274 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Pest control + other interventions vs. placebo or no intervention | Health care utilization and costs: school absenteeism/patient activities | Improvement: Significantly fewer days with activity limitations in 2 RCTs of 1,211 youths. Significantly fewer missed school days in RCT of 937 children, but no difference in RCT of 274 children. | 4 RCTs^65–67,78^ n=1,609 | Low (Study limitations, Inconsistent)
Pest control + other interventions vs. placebo or no intervention | Health care utilization and costs: work absenteeism/caretaker plans | No effect: No difference in missed days of work or caretaker plans changed in 2 RCTs of 1,211 children. | 2 RCTs^66,67^ | Low (Study limitations, Imprecise)
Pest control + other interventions vs. placebo or no intervention | Pulmonary physiology: peak flow | Inconclusive: Significant increase in peak flow in RCT of 298 children. No difference in peak flow variability. | 1 RCT^65^ n=298 | Insufficient (Study limitations, Unknown consistency, Imprecise)
Pest control + other interventions vs. placebo or no intervention | Pulmonary physiology: FEV_1_ | Inconclusive: Significant increase in FEV_1_ from baseline (but no comparison between groups) in RCT of 298 children. No difference between groups in FEV_1_ in RCT of 937 children and RCT of 361 mixed-population subjects. | 3 RCTs^63,65,67^ n=1,596 | Insufficient (Inconsistent, Imprecise) ^**^Substantial imprecision
Pest control + other interventions vs. placebo or no intervention | Quality of life: PACQLQ | Improvement: PACQLQ score improved significantly in RCT of 274 children. | 1 RCT^66^ N=274 | Low (Study limitations, Unknown consistency)
Pest control + other interventions vs. placebo or no intervention | Quality of life: other measures | Inconclusive: No difference in RCT of 100 children in composite quality-of-life score (domains not described). | 1 RCT^78^ N=100 | Insufficient (Unknown consistency, Imprecise) ^**^Substantial imprecision
Pest control + other interventions vs. placebo or no intervention | Symptoms (secondary measure) | Improved symptoms: Significant decrease in symptom days or frequency of symptoms in 5 RCTs of 2,529 children. No difference in symptom days in RCT of 274 children and RCT of 361 mixed-population subjects. No difference in cough or wheeze in 2 RCTs of 545 mixed-population subjects. | 9 RCTs^63,65–67,69–71, 78,86^ n=3,709 | Low (Study limitations, Inconsistency)
Pest control + other interventions vs. placebo or no intervention | Allergen levels: cockroach (secondary measure) | Reduction: Significant reduction in cockroach allergen in RCT of 937 children. No difference in RCT of 100 children. Significant reduction at 4 and 8 months but not 12 months in RCT of 161 children. | 3 RCTs^67,71,78^ n=1,198 | Low (Inconsistent, Imprecise)
Pest control + other interventions vs. placebo or no intervention | Allergen levels: mouse (secondary measure) | Inconclusive: Significant reduction in mouse allergen in RCT of 937 children and RCT of 361 mixed-population subjects. No difference in 2 RCTs of 398 children. | 4 RCTs^65,67,78^ n=1,696 | Insufficient (Inconsistent, Imprecise) ^**^Substantial inconsistency

* Outcomes of Asthma control, Exacerbations, Healthcare utilization, and Pulmonary physiology as defined by Asthma Outcomes workshop;^31^ outcomes of Quality of life, Symptoms, and Allergen levels as defined by study authors.

** Criteria for downgrading strength of evidence is described as Rationale; when these criteria are insufficient for understanding the final strength of evidence, additional explanation is provided.

ACT=asthma control test; AQLQ=asthma quality of life questionnaire; Bla g=blatella germanica cockroach allergen; CHSA=children’s health survey for asthma; Der f=dermatophagoides farina allergen; Der p=dermatophagoides pteronyssinus allergen; ED=emergency department; FEV_1_=forced expiratory volume in 1 second; HDM=house dust mite; HEPA=high-efficiency particulate air-filtration; Mus m=mus musculus mouse allergen; NA=not available; PACQLQ=pediatric asthma caregivers asthma quality of life questionnaire; RCT=randomized controlled trial

### Detailed Synthesis

#### Studies of Single Component/Individual Interventions

Individual interventions for which we identified studies include treatment of mattresses and carpets with acaricide, use of air purifiers, HEPA vacuuming, mattress covers, pest control, and pet removal. We also found one study of commercially available household cleaning products containing bleach or other disinfectants.

No adverse events were reported from the studies we examined. While many studies reported on pulmonary physiology, nonvalidated measures of respiratory symptoms, and allergen levels, few studies reported validated measures of asthma control or quality of life. Additionally, rates of exacerbations and health care utilization were often low or not reported.

##### Acaricide (Dust Mite Pesticide)

Four RCTs^24–27^ compared the use of acaricide with placebo. One additional RCT^28^ compared acaricide with other HDM-avoidance interventions. Another RCT^29^ and a quasi-experimental study^30^ had three arms comparing the use of acaricide with placebo and with other HDM- avoidance interventions. Treatments were used on carpets, upholstery, and mattresses in the bedroom and typically applied in the most commonly used residential room. Followup ranged from three to 6 months. The trials reported that all enrolled patients demonstrated allergic sensitization to HDM allergen. Six studies used skin-prick testing to confirm sensitization, while one trial used blood tests. Acaricide manufacturers funded two studies but did not report positive findings, and we did not detect publication or reporting bias in this evidence base. The studies did not report measures of asthma control, exacerbations, and health care utilization. Use of acaricide was associated with no change in pulmonary physiology compared with placebo (SOE: moderate) or other interventions (SOE: low). The findings for quality of life were inconclusive, and interpretation of the findings was limited by poor reporting of data and statistical analyses and small sample sizes. Table 4 presents the findings and SOE ratings for the outcomes these studies assessed.

##### Air Purification Interventions

Seven of nine RCTs compared the use of air purification systems to either a sham intervention^32–36^ or no intervention.^37,38^ An additional RCT^39^ compared the use of air filtration with other HDM-avoidance interventions. Finally, another study installed new mechanical heat-recovery ventilation in the home, with sham fans as a control.^40^ Five of the studies implemented air purification in both bedrooms and living rooms, while three studies focused only on bedroom air (the mechanical ventilation study affected air throughout participants’ homes.) Followup ranged from 4 weeks to 12 months. Six of the nine studies reported that all patients were sensitized to at least one allergen of interest that was potentially subject to the effects of the intervention, usually HDM, cat, or dog (four of these trials used skin- prick tests, and two used blood tests). Three other studies found that 70 to 95 percent of patients were sensitized to one of these allergens (two used skin-prick tests, and one used blood tests). Air filtration device manufacturers funded three studies, but we did not detect publication or reporting bias in this evidence base because the industry-funded studies were not associated with better results than non-industry-funded studies of air purifiers.

The effect of air purification interventions on asthma control was inconclusive, and exacerbations were not reported. There was no difference in health care utilization (SOE:lLow) and pulmonary physiology. For quality of life, one study found that Asthma Quality Control Questionnaire (AQLQ) scores improved (SOE: low), while two studies that used nonvalidated quality of life measures found no effect (SOE: low). Interpretation of all the findings reported for air purification interventions was limited by poor reporting of data and statistical analyses, lack of between-group comparisons, and small sample sizes. Table 5 presents the findings and SOE ratings for the outcomes these studies assessed.

##### Carpet Removal

We did not identify any studies that examined carpet removal as a solitary intervention to improve asthma outcomes. Carpet removal was included as a strategy in several multicomponent interventions that are described in the multicomponent study section below.

##### HEPA Vacuum Interventions

One small RCT^41^ compared the use of HEPA vacuums on carpets and soft furnishings with standard vacuums. Participants were instructed to vacuum the sofa, mattress, and living room and bedroom carpet at least once a week for up to one year. All patients were sensitized to HDM based on skin-prick tests, and a majority of those who owned a cat were also allergic to cat allergen. This study was not funded by an industry source, although one coauthor reported having received funding from a vacuum manufacturer. Measures of asthma control, exacerbations, health care utilization, or quality of life were not reported. Use of HEPA vacuums led to improvements in spirometry measures compared with the standard vacuums, but the overall SOE was Insufficient. Use of HEPA vacuums reduced the secondary measure of allergen levels compared with baseline for some areas of the home and some of the allergens measured, but most areas and allergens did not vary with use of the HEPA vacuum. In addition, between-group comparisons were not reported, limiting interpretation of the findings. Table 6 presents the findings and SOE ratings for the outcomes this study assessed.

##### Mattress Cover Interventions

Seventeen RCTs examined the effectiveness of mattress covers or other interventions related to bedding. Ten of these RCTs^42–51^ compared the use of impermeable mattress covers with placebo, and four other RCTs^52–55^ compared covers with no intervention. We combined these 14 studies for analysis. An additional three RCTs evaluated different interventions: one^56^ compared feather-filled pillows and quilts plus impermeable mattress covers with impermeable mattress covers alone; one^57^ compared an impermeable pillow designed to resist HDM without any additional covering with a placebo pillow; and one^58^ examined the effectiveness of boiling bed covers in hot water for 10 minutes and exposing them to sunlight for 3 hours every 2 weeks, compared with standard linen washing practices. None of the studies were conducted in the United States, and most were small; 9 studies included fewer than 50 patients, and only 5 studies included more than 100 patients. Ten studies included only patients age 12 or older, 6 included both adults and youths below age 12, and the study of the impermeable pillow enrolled only children. One study did not report the ages of enrolled participants.

Sixteen of the 17 studies confirmed that all patients demonstrated sensitization to HDM allergens, with 10 of these trials confirming sensitization using skin-prick tests. Only 7 studies described randomization and allocation practices, but 11 studies blinded both patients and outcome assessors. No studies reported direct funding by mattress cover manufacturers, although one study included two coauthors who had received funding from a manufacturer. Individual study risk of bias was not considered a limitation of the evidence base addressing mattress covers.

Mattress cover interventions showed no effect was observed for asthma control (SOE: moderate), exacerbations (SOE: moderate), use of inhaled corticosteroids (SOE: low), use of rescue medication (SOE: high), pulmonary physiology (SOE: high), or quality of life (SOE: high). However, the evidence suggests that HDM allergen exposure levels were significantly reduced by use of mattress covers (SOE: moderate) despite the lack of clinical improvement. Findings for the three studies that did not evaluate mattress covers were inconclusive. Table 7 presents the findings and SOE ratings for the outcomes these studies assessed.

##### Mold Removal

We did not identify any studies that examined mold removal as a solitary intervention to improve asthma outcomes. Mold removal was included as a strategy in several multicomponent interventions that are described in the multicomponent study section below.

##### Pest Control Interventions

One RCT^59^ and one pre-post study^60^ examined pest-reduction interventions targeted primarily at cockroach (the RCT) and rodent (the pre-post study) elimination. The RCT^59^ compared use of insecticide bait, placed in cockroach-sensitive areas by pest control professionals, with no intervention. Followup time was one year. Only 27 percent of patients were sensitized to cockroach allergen, while 12 percent were sensitized to mouse allergen and 50 percent were sensitized to HDM allergen, all based on blood tests.

The pre-post study^60^ was conducted in public housing in Boston, Massachusetts, and consisted of a one-time deep-cleaning of the home, setting traps, sealing rodent access points, replacing mattresses, providing education about kitchen hygiene and food storage, reducing clutter, and communicating with housing authority and pest contractors. Followup times varied, with a maximum followup of 66 weeks. Sixty percent of patients were sensitized to HDM allergens, while 58 percent reported sensitization to cockroach allergen, as confirmed by skin- prick tests.

Measures of primary outcomes were inconclusive. However, respiratory symptoms were shown to improve. Lack of precision in reporting the findings and small sample size limit the ability to draw conclusions regarding effectiveness of the interventions. Table 8 presents the findings and SOE ratings for the outcomes these studies assessed

##### Pet Care and Removal

We identified one non-RCT^61^ that examined pet removal as a solitary intervention to improve asthma outcomes. The intervention was conducted in patients with asthma in Japan and consisted of voluntary removal of pets from the home. The study involved two small cohorts of patients who removed pets following clinician advice and those who kept pets against clinician advice. Latency for pet removal from patient homes ranged from within 1 month of clinician advice up to 16 months following advice. Followup times varied, with a maximum followup of 43 months. All patients were sensitized to house pet allergens, based on skin-prick tests. Most patients were sensitized to other allergens, including cedar pollen, HDM, and grass pollens. Measures of asthma control, pulmonary physiology, and quality of life were not reported. The evidence for exacerbations and health care utilization was inconclusive. Over time, use of inhaled corticosteroid was eliminated in patients who removed their pets, and followup visits to the medical office were statistically significantly reduced in the pet-removal group compared with those who kept their pets. Lack of precision in reporting the findings and small sample size limit the ability to draw conclusions regarding effectiveness of the intervention. Table 9 presents the findings and SOE ratings for the outcomes this study assessed.

##### Other Interventions: Cleaning Products

One RCT^62^ examined the provision and use of common household cleaning products used for cleaning counters, floors, bathrooms, and other surfaces. These products were compared with no provision of or instructions regarding cleaning products. A manufacturer of cleaning products funded the study, and the authors did not report how many patients were sensitized to specific allergens. In this eight-week study, measures of asthma control and exacerbations were inconclusive. Health care utilization and pulmonary physiology outcomes were not reported. Furthermore, the main outcome of quality of life was improved in all groups, including the no-cleaning-product group, and the authors suggest the possibility of a placebo effect of keeping diaries on quality of life. Secondary asthma symptom outcomes were improved with use of any experimentally provided cleaner compared with no cleaning product. However, allergen levels measured in dust samples were not affected by cleaning products. Table 10 presents the findings and SOE ratings for the outcomes this study assessed.

#### Studies of Multicomponent Interventions

Twenty-five RCTs,^63–87^ two nonrandomized trials with concurrent controls,^88,89^ and three pre–post studies^90–92^ examined interventions that bundled multiple allergen-avoidance strategies. Six of the 30 studies included application of an acaricide to carpeting. Five studies used air- filtration devices. Eight studies recommended or required removal of carpeting in living rooms, bedrooms, or both. Eight studies provided participants with HEPA vacuums. Nineteen studies included use of impermeable mattress covers. Six studies included an intervention intended to reduce or remove mold. Thirteen studies implemented pest control strategies. Two studies suggested pet removal to reduce pet-related allergens. In nine studies, patients were provided general cleaning supplies to help minimize allergens, dust, dirt, and other irritants. Additionally, 11 studies featured a community health worker, social worker, or study team member who visited patient homes to provide direct, tailored education about management of the home environment and offer instruction in the proper use of intervention tools such as mattress covers or vacuums. Finally, 13 studies included some other type of intervention as well, addressing a wide range of potential strategies.

Twenty of the 30 studies were conducted in the United States. Seven studies were conducted exclusively in children, 5 studies enrolled adults and youths age 12 or older, and the remaining 18 studies included all populations. Most of the studies have important limitations that increase potential risk of bias: only 7 of 25 RCTs described an acceptable randomization protocol, just 4 described a procedure for allocation concealment, and 9 included blinding of both patients and outcome assessors. Attrition was also a substantial limitation, with 12 RCTs reporting attrition rates exceeding 15 percent. Only one study reported funding from a commercial source that manufactured the intervention that was studied. Twenty studies judged risk of bias from selective outcome reporting to be low, and 13 studies judged risk of bias from incomplete data reporting to be low. Detailed information on risk of bias for all studies is found in Appendix C.

Another important factor is whether sensitization to the relevant allergen (targeted by the intervention) was assessed in participants before the intervention. Of the 25 RCTs, 11 reported that all enrolled patients were allergic to at least 1 allergen of interest (usually HDM), confirmed in 10 studies by a positive skin-prick test, and with blood tests in the other trial. Seven other RCTs reported that a majority of patients were sensitized (5 studies used skin-prick tests, and 2 used blood tests for confirmation), while four reported lower rates (3 used skin-prick tests, and 1 used blood tests for confirmation). Three studies did not report sensitization in the study participants.

Fifteen of 30 of the multicomponent intervention studies reported the secondary, intermediate outcome of allergen reduction in addition to at least 1 primary outcome. Ten of the studies demonstrated internal consistency between allergen reduction findings and clinical outcomes: seven studies showed significant reduction in allergen levels and significant improvement in at least one primary outcome, while three studies found no reduction in allergens detected and no improvement in clinical outcomes. Only five studies reported significant reductions in allergens but no corresponding improvement in primary outcomes, and no individual studies showed improvement in primary outcomes without evidence of reduced allergen levels.

Given the substantial heterogeneity in the combination of interventions used in these multicomponent studies, as well as variability in implementation and adherence to the interventions, we organized the SOE analysis according to the concept of “grouping by active component.”^93^ In this approach, each active component was examined by synthesizing the studies that shared a common element in the intervention arm (e.g., use of acaricide), without regard to the other active intervention components in those studies. The “active” components are interventions that were present in each study’s intervention arm but not the control arm and are within this review’s scope. These active components correlate with the single intervention studies described above: acaricide, air purification, carpet removal, HEPA vacuums, mattress covers, mold removal, pest control, and pet removal. A study that had three different active interventions (e.g., HEPA vacuum, mattress cover, pest control) would therefore be included in the SOE table three different times as it was combined with other studies that shared each respective active intervention. Although this approach limits our confidence in the results by temporarily attributing the outcomes of a complex study to only one of its components in each analysis, we believe this is the best approach to synthesize this evidence in the context of a highly heterogeneous evidence base.

We also considered two alternative analytic approaches. First, we attempted to group the studies into “bundles” that could be characterized by a set of shared components. This was not feasible, however, because the specific combinations of interventions were too diverse, and this approach would have yielded many sets of bundles with minimal numbers of studies in each set. A second approach was to compare studies that had positive findings (i.e., improvement in the primary clinical outcomes) with studies that found no effect and identify differences in the types of interventions used. This analysis did not detect a pattern of intervention components that was more likely to be present in positive studies. After feedback from peer and public reviewers and AHRQ, we conducted QCA to supplement this assessment of the multicomponent interventions.

Some of the interventions that appear frequently in the studies are excluded from this analysis because they are outside the scope of the review (e.g., community health workers providing education beyond information on allergen reduction strategies). Additionally, pet removal was not assessed because it was a component of only two studies, and within those studies, pet ownership was not an inclusion criterion (i.e., any participants who had pets were encouraged to remove them or restrict their access, but the intervention was not standardized). Table 11 presents an overview of the interventions by study. Table 12 presents the findings and SOE for each primary active component and key outcomes.

#### Qualitative Comparative Analysis

##### Inputs

We included single intervention as well as multicomponent intervention studies in the analysis. Although the initial decision to conduct a qualitative comparative analysis (QCA) assessment was intended to refine our review of multicomponent interventions, we did not restrict the analysis to those studies. Including both single and multicomponent trials in the model provided two benefits: (1) expanding the number of studies enabled a more robust analysis; and (2) we could search for effects potentially associated with each intervention across single and multicomponent studies.

The analysis included 49 studies. We excluded studies that were not RCTs, studies that did not include one of the six interventions that we assessed for both single and multicomponent trials, and studies that did not report usable data for at least one primary outcome.

To simplify the model we created a composite outcome measure. Each study that demonstrated at least one statistically significant beneficial effect on any of the primary outcomes was coded as having a “positive outcome.” Each study that found no effect on every primary outcome measure it reported was coded as having a “negative outcome.” This dichotomous approach was selected to maximize the possibility of finding an effect and was expected to be necessary given the relatively few studies in this review that reported positive findings.

##### Step 1 Testing for Necessary or Sufficient Conditions

One parameter of fit-for-testing necessity and sufficiency of each discrete intervention is consistency, displayed in Table 13. Consistency assesses whether the causal pathway produces the outcome regularly. Consistency estimates for necessity range between 0.136 and 0.545. Consistency estimates for sufficiency range between 0.417 and 0.714. None of these values exceed the standard consistency threshold of ≥0.9. Thus, these results suggest that no individual intervention, whether implemented alone or as part of a multicomponent strategy, is either necessary or sufficient to improve asthma outcomes. This does not mean that these interventions are not effective; rather, it may suggest that further research is needed to better evaluate the effectiveness of both single and multicomponent strategies.

Table 13 Results of consistency analyses: necessity and sufficiency of interventions

Conditions | Necessity | Sufficiency
Acaricides (dust mite pesticide) | 0.227 | 0.455
Air purification | 0.227 | 0.417
Carpet removal | 0.136 | 0.600
HEPA vacuum | 0.227 | 0.714
Mattress covers | 0.545 | 0.429
Pest control | 0.227 | 0.500

HEPA=high-efficiency particulate air-filtration

##### Step 2 Constructing the Truth Table

We examined six interventions; therefore, the truth table has 2^6^ = 64 rows representing all logically possible combinations of these conditions. The truth table is presented in Table 14. Only five configuration sets lead to the presence of a positive outcome (i.e., Outcome = 1), with high consistency scores. Conversely, there are many remainders, which are combinations of interventions and outcomes that theoretically could exist, but were not present in any of the included studies. Also, six configurations lead to contradictory outcomes (i.e., Outcome = “C”), indicating that identical allergen reduction strategies resulted in some studies that found beneficial effects and others that did not.

Table 14 Truth table for allergen reduction interventions

Configuration | Acaricide | Air Purification | Carpet Removal | HEPA Vacuum | Mattress Cover | Pest Control | Outcome | n | Consistency
2 | 0 | 0 | 0 | 0 | 0 | 1 | C | 2 | 0.500
3 | 0 | 0 | 0 | 0 | 1 | 0 | C | 14 | 0.357
4 | 0 | 0 | 0 | 0 | 1 | 1 | C | 2 | 0.500
5 | 0 | 0 | 0 | 1 | 0 | 0 | C | 3 | 0.667
6 | 0 | 0 | 0 | 1 | 0 | 1 | 1 | 1 | 1.000
8 | 0 | 0 | 0 | 1 | 1 | 1 | 1 | 1 | 1.000
9 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1.000
12 | 0 | 0 | 1 | 0 | 1 | 1 | 0 | 2 | 0.000
17 | 0 | 1 | 0 | 0 | 0 | 0 | C | 9 | 0.444
20 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 1 | 0.000
23 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 1 | 0.000
24 | 0 | 1 | 0 | 1 | 1 | 1 | 1 | 1 | 1.000
33 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 5 | 0.200
35 | 1 | 0 | 0 | 0 | 1 | 0 | C | 4 | 0.500
43 | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 2 | 1.000

For columns identifying interventions (Acaricide, Air Purification, Carpet Removal, HEPA Vacuum, Mattress Cover, and Pest Control), “1” indicates that the specific intervention was included in the given configuration, and “0” indicates that the specific intervention was not included in the given configuration; For the column identifying Outcome, “1” indicates that all studies using the given configuration reported a positive result for at least one primary outcome, “0” indicates that all studies using the given configuration reported no positive results for any primary outcome, and “C” indicates that the studies were contradictory, with at least one study reporting at least one positive result while at least one other study reported no positive results; Configurations where all included studies reported at least one positive result are in bold

HEPA= high-efficiency particulate air-filtration

##### Step 3 Solutions

Our analysis included 49 studies, with only 22 that showed significant improvement in at least 1 primary outcome. The Boolean analysis of the truth table found no conditions that were necessary, either individually or in combination. Therefore, no intervention or bundle of strategies appears to be required to produce improvement in asthma outcomes.

Analysis of sufficient combinations identified two solutions, each with 100 percent consistency. These solutions, shown in Figure 4, were use of carpet removal without use of pest control and combined use of a HEPA vacuum and pest control. The first solution may not have an empirical explanation and might be an artifact of the few studies evaluated. Three studies used carpet removal, did not use pest control, and found improvement in asthma outcomes. One of these studies used only carpet removal, while the other two studies also used mattress covers and acaricides. Conversely, two studies that used carpet removal as well as pest control found no improvements in outcomes, but these studies also used mattress covers. Further, five other included studies with positive results used pest control. We conclude that it is unlikely that avoidance of pest control is inherently associated with better asthma outcomes when carpet is removed.

Figure 4 Solutions for qualitative comparative analysis

cov.r= raw coverage, or how much of the outcome is represented by the given configuration; cov.u= unique coverage, or how much of the outcome is represented by only the given configuration and no other configurations; HEPA= high-efficiency particulate air-filtration; PRI= proportional reduction in inconsistency

Figure 4 shows the intermediate solution set derived from QCA. Based on 49 studies included in this analysis, there were two solutions. Solution 1 includes carpet removal without pest control. Solution 2 includes HEPA vacuums with pest control. Each solution has a small range of coverage. The total coverage provided by both solutions is 0.273, or approximately 27% of all studies with a positive outcome.

The second solution includes use of a HEPA vacuum paired with pest control. Three studies used this combination, and all three resulted in improvement. However, these studies varied in study design. One of the three studies used only vacuums and pest control, one also used mattress covers, and a third used mattress covers and air purification devices, in addition to vacuums and pest control interventions. Therefore, although the combination of HEPA vacuums and pest control might logically improve outcomes by routinely addressing multiple types of allergens, the evidence base is too small to support any strong conclusions.

A final limitation of these solutions is the small coverage they provide. Coverage refers to how many studies with positive outcomes are included in the solutions, and thus demonstrates whether the solution combinations we identified can explain most of the positive findings in the literature. Taken together, our two solutions have 27 percent coverage, accounting for just 6 of the 22 studies that reported improvement in primary asthma outcomes. This is a very low estimate, and suggests that we cannot confidently determine whether specific combinations of interventions are likely to improve outcomes.