# References

1 National Heart, Lung, and Blood Institute. Expert panel report 3: guidelines for the diagnosis and management of asthma. [internet]. Bethesda (MD): National Institutes of Health (NIH); 2007 Jan 01 [accessed 2013 Jun 01]. Available: http://www.nhlbi.nih.gov/guidelines/asthma/.
2 Most recent asthma data. [internet]. Atlanta (GA): Centers for Disease Control and Prevention (CDC); [accessed 2016 Jul 05]. Available: http:www.cdc.gov/asthma/most_recent_data.htm.
3 Trends in asthma morbidity and mortality. Chicago (IL): American Lung Association; 2012 Sep. 26 p. Also available: http://www.lung.org/assets/documents/research/asthma-trend-report.pdf.
4 The global asthma report 2014. Aukland, New Zealand: Global Asthma Network; 2014. 92 p. Also available: http://www.globalasthmareport.org/resources/Global_Asthma_Report_2014.pdf.
5 Asthma national health statistics. [internet]. Atlanta (GA): Centers for Disease Control and Prevention (CDC); [accessed 2016 Apr 01]. Available: http://www.cdc.gov/nchs/fastats/asthma.htm.
6 Asthma overview. [internet]. Milwaukee (WI): American Academy of Allergy Asthma & Immunology; [accessed 2016 Apr 07]. [2 p]. Available: http://www.aaaai.org/conditions-and-treatments/asthma.
7 Sicherer SH, Leung DYM. Advances in allergic skin disease, anaphylaxis, and hypersensitivity reactions to foods, drugs, and insects in 2007. J Allergy Clin Immunol. 2008 Jun;121(6):1351–8. Also available: http://dx.doi.org/10.1016/j.jaci.2008.01.032. PMID: 18325575.18325575
8 Draft needs assessment report for potential update of the Expert Panel Report-3 (2007): guidelines for the diagnosis and management of asthma. Bethesda (MD): National Heart, Lung, and Blood Institute (NHLBI); 2015 Jan. 14 p. Also available: https://www.nhlbi.nih.gov/sites/www.nhlbi.nih.gov/files/NHLBAC_Asthma-WG-Report-2015[1].pdf.
9 The effectiveness of indoor allergen reduction and the role of bronchialthermoplasty in the management of asthma. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2016 Oct 4. 18 p. (Evidence-based Practice Center Systematic Review Protocol; Also available: https://effectivehealthcare.ahrq.gov/ehc/products/643/2318/asthma-nonpharmacologic-treatment-protocol-161004.pdf.
10 Leas B, D’Anci K, Apter A, . The effectiveness of indoor allergen reduction and the role of bronchial thermoplasty in the management of asthma. PROSPERO 2017:CRD42017055547 Available from http://www.crd.york.ac.uk/PROSPERO/display_record.asp?ID=CRD42017055547.
11 Chalmers I, Adams M, Dickersin K, . A cohort study of summary reports of controlled trials. JAMA. 1990 Mar 9;263(10):1401–5. PMID: 2304219.2304219
12 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. 1987 Mar;8(2):198–203. PMID: 3818406.3818406
13 Dundar Y, Dodd S, Williamson P, . Case study of the comparison of data from conference abstracts and full-text articles in health technology assessment of rapidly evolving technologies: does it make a difference? Int J Technol Assess Health Care. 2006 Jul;22(3):288–94.16984055
14 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. 1992 Mar;3(3):187–91. PMID: 1586615.1586615
15 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. In: Cochrane Library [Cochrane methodology review]. Issue 2. Oxford: Update Software; 2001 [accessed 2001 Apr 23]. [35 p]. Available: http://www.cochrane.org/index.htm.
16 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. 1993 Jul;40(7):632–4. PMID: 8403137.8403137
17 Marx WF, Cloft HJ, Do HM, . The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. AJNR Am J Neuroradiol. 1999 Jun–Jul;20(6):1173–7. PMID: 10445467.10445467
18 Cochrane handbook for systematic reviews of interventions. Version 5.1.0. [database online]. Hoboken (NJ): John Wiley & Sons, Ltd.; 2011 Mar 20 [accessed 2012 Dec 04]. [various p.]. Available: http://handbook.cochrane.org/.
19 Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analysis [manuals and scales]. [internet]. Ottawa, Ontario: Ottawa Health Research Institute; [accessed 2004 Jul 26]. [7 p]. Available: http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm.
20 Forman-Hoffman VL, Cook Middleton J, McKeeman JL, . Strategies to improve mental health care for children and adolescents. (Prepared by the RTI International--University of North Carolina Evidence-based Practice Center under Contract No. 290–2012- 00008-I.) AHRQ Publication No. 16(17)-EHC035-EF. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2016 Dec. (Comparative Effectiveness Review; no.181). Also available: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
21 Kahwati L, Jacobs S, Kane H, . Using qualitative comparative analysis in a systematic review of a complex intervention. Syst Rev. 2016 May 04;5:82. Also available: http://dx.doi.org/10.1186/s13643-016-0256-y. PMID: 27209206.27209206
22 Kahwati L, Viswanathan M, Golin CE, . Identifying configurations of behavior change techniques in effective medication adherence interventions: a qualitative comparative analysis. Syst Rev. 2016 May 04;5:83. Also available: http://dx.doi.org/10.1186/s13643-016-0255-z. PMID: 27209092.27209092
23 Ragin CC. Using qualitative comparative analysis to study causal complexity. Health Serv Res. 1999 Dec;34(5 Pt 2):1225–39. PMID: 10591281.10591281
24 Geller-Bernstein C, Pibourdin JM, Dornelas A, . Efficacy of the acaricide: acardust for the prevention of asthma and rhinitis due to dust mite allergy, in children. Allerg Immunol (Paris). 1995;27(5):147–54. PMID: 7662102.7662102
25 Sette L, Comis A, Marcucci F, . Benzyl-benzoate foam: effects on mite allergens in mattress, serum and nasal secretory IgE to dermatophagoides pteronyssinus, and bronchial hyperreactivity in children with allergic asthma. Pediatr Pulmonol. 1994 Oct;18(4):218–27. PMID: 7838620.7838620
26 Dietemann A, Bessot JC, Hoyet C, . A double-blind, placebo controlled trial of solidified benzyl benzoate applied in dwellings of asthmatic patients sensitive to mites: clinical efficacy and effect on mite allergens. J Allergy Clin Immunol. 1993;91(3):738–46. PMID: 8454796.8454796
27 Reiser J, Ingram D, Mitchell EB, . House dust mite allergen levels and an anti-mite mattress spray (natamycin) in the treatment of childhood asthma. Clin Exp Allergy. 1990;20(5):561–7. PMID: 2253088.2253088
28 Chang JH, Becker A, Ferguson A, . Effect of application of benzyl benzoate on house dust mite allergen levels. Ann Allergy Asthma Immunol. 1996 Sep;77(3):187–90. PMID: 8814042.8814042
29 Bahir A, Goldberg A, Mekori YA, . Continuous avoidance measures with or without acaricide in dust mite-allergic asthmatic children. Ann Allergy Asthma Immunol. 1997 May;78(5):506–12. PMID: 9164365.9164365
30 van der Heide S, Kauffman HF, Dubois AE, . Allergen-avoidance measures in homes of house-dust-mite-allergic asthmatic patients: effects of acaricides and mattress encasings. Allergy. 1997;52(9):921–7. PMID: 9298177.9298177
31 Busse WW, Morgan WJ, Taggart V, . Asthma outcomes workshop: overview. J. Allergy Clin. Immunol. 2012 Mar;129(3 Suppl):S1–8. Also available: http://dx.doi.org/10.1016/j.jaci.2011.12.985. PMID: 22386504.22386504
32 Pedroletti C, Millinger E, Dahlén B, . Clinical effects of purified air administered to the breathing zone in allergic asthma: a double-blind randomized cross-over trial. Respir Med. 2009 Sep;103(9):1313–9. Also available: http://dx.doi.org/10.1016/j.rmed.2009.03.020. PMID: 19443189.19443189
33 Sulser C, Schulz G, Wagner P, . Can the use of HEPA cleaners in homes of asthmatic children and adolescents sensitized to cat and dog allergens decrease bronchial hyperresponsiveness and allergen contents in solid dust? Int Arch Allergy Immunol. 2008 Dec;148(1):23–30. Also available: http://dx.doi.org/10.1159/000151502. PMID: 18716400.18716400
34 van der Heide S, van Aalderen WM, Kauffman HF, . Clinical effects of air cleaners in homes of asthmatic children sensitized to pet allergens. J Allergy Clin Immunol. 1999;104(2):447–51. Also available: http://dx.doi.org/10.1016/S0091-6749(99)70391-X. PMID: 10452769.10452769
35 Warner JA, Marchant JL, Warner JO. Double blind trial of ionisers in children with asthma sensitive to the house dust mite. Thorax. 1993;48(4):330–3. PMID: 8511730.8511730
36 Zwemer RJ, Karibo J. Use of laminar control device as adjunct to standard environmental control measures in symptomatic asthmatic children. Ann Allergy. 1973 Jun;31(6):284–90. PMID: 4710748.4710748
37 Francis H, Fletcher G, Anthony C, . Clinical effects of air filters in homes of asthmatic adults sensitized and exposed to pet allergens. Clin Exp Allergy. 2003;33(1):101–5. Also available: http://dx.doi.org/10.1046/j.1365-2222.2003.01570.x. PMID: 12534557.12534557
38 Mitchell EA, Elliott RB. Controlled trial of an electrostatic precipitator in childhood asthma. Lancet. 1980 Sep 13;2(8194):559–61. PMID: 6106739.6106739
39 van der Heide S, Kauffman HF, Dubois AE, . Allergen reduction measures in houses of allergic asthmatic patients: effects of air-cleaners and allergen-impermeable mattress covers. Eur Respir J. 1997 Jun;10(6):1217–23. Also available: http://dx.doi.org/10.1183/09031936.97.10061217. PMID: 9192919.9192919
40 Wright GR, Howieson S, McSharry C, . Effect of improved home ventilation on asthma control and house dust mite allergen levels. Allergy. 2009 Nov;64(11):1671–80. Also available: http://dx.doi.org/10.1111/j.1398-9995.2009.02098.x. PMID: 19650848.19650848
41 Popplewell EJ, Innes VA, Lloyd-Hughes S, . The effect of high-efficiency and standard vacuum-cleaners on mite, cat and dog allergen levels and clinical progress. Pediatr Allergy Immunol. 2000;11(3):142–8. Also available: http://dx.doi.org/10.1034/j.1399-3038.2000.00058.x. PMID: 10981523.10981523
42 Murray CS, Foden P, Sumner H, . Preventing severe asthma exacerbations in children: a randomised trial of mite impermeable bedcovers. Am J Respir Crit Care Med. 2017 Mar 10. [Epub ahead of print]. Also available: http://dx.doi.org/10.1164/rccm.201609-1966OC. PMID: 28282501.28282501
43 de Vries MP, van den Bemt L, Aretz K, . House dust mite allergen avoidance and self-management in allergic patients with asthma: randomised controlled trial. Br J Gen Pract. 2007 Mar;57(536):184–90. PMID: 17359604.17359604
44 Dharmage S, Walters EH, Thien F, . Encasement of bedding does not improve asthma in atopic adult asthmatics. Int Arch Allergy Immunol. 2006 Jan;139(2):132–8. Also available: http://dx.doi.org/10.1159/000090388. PMID: 16374022.16374022
45 van den Bemt L, van Knapen L, de Vries MP, . Clinical effectiveness of a mite allergen-impermeable bed-covering system in asthmatic mite-sensitive patients. J Allergy Clin Immunol. 2004 Oct;114(4):858–62. Also available: http://dx.doi.org/10.1016/j.jaci.2004.05.069. PMID: 15480327.15480327
46 Halken S, Host A, Niklassen U, . Effect of mattress and pillow encasings on children with asthma and house dust mite allergy. J Allergy Clin Immunol. 2003 Jan 1;111(1):169–76. Also available: http://dx.doi.org/10.1067/mai.2003.5. PMID: 12532114.12532114
47 Luczynska C, Tredwell E, Smeeton N, . A randomized controlled trial of mite allergen-impermeable bed covers in adult mite-sensitized asthmatics. Clin Exp Allergy. 2003 Dec;33(12):1648–53. Also available: http://dx.doi.org/10.1111/j.1365-2222.2003.01729.x. PMID: 14656350.14656350
48 Woodcock A, Forster L, Matthews E, . Control of exposure to mite allergen and allergen-impermeable bed covers for adults with asthma. N Engl J Med. 2003 Jul 17;349(3):225–36. Also available: http://dx.doi.org/10.1056/NEJMoa023175. PMID: 12867606.12867606
49 Rijssenbeek-Nouwens LH, Oosting AJ, de Bruin-Weller MS, . Clinical evaluation of the effect of anti-allergic mattress covers in patients with moderate to severe asthma and house dust mite allergy: a randomised double blind placebo controlled study. Thorax. 2002 Sep;57(9):784–90. Also available: http://dx.doi.org/10.1136/thorax.57.9.784. PMID: 12200523.12200523
50 Sheikh A, Hurwitz B, Sibbald B, . House dust mite barrier bedding for childhood asthma: randomised placebocontrolled trial in primary care [ISRCTN63308372]. BMC Fam Pract. 2002 Jun 18;1–6. PMID: 12079502.11835692
51 Frederick JM, Warner JO, Jessop WJ, . Effect of a bed covering system in children with asthma and house dust mite hypersensitivity. Eur Respir J. 1997 Feb;10(2):361–6. Also available: http://dx.doi.org/10.1183/09031936.97.10020361. PMID: 9042633.9042633
52 Tsurikisawa N, Saito A, Oshikata C, . Encasing bedding in covers made of microfine fibers reduces exposure to house mite allergens and improves disease management in adult atopic asthmatics. Allergy Asthma Clin Immunol. 2013;9(1):44. Also available: http://dx.doi.org/10.1186/1710-1492-9-44. PMID: 24499343.24499343
53 Burr ML, Neale E, Dean BV, . Effect of a change to mite-free bedding on children with mite-sensitive asthma: a controlled trial. Thorax. 1980 Jul;35(7):513–4. PMID: 7001668.7001668
54 Burr ML, St Leger AS, Neale E. Anti-mite measurements in mite-sensitive adult asthma. A controlled trial. Lancet. 1976 Feb 14;1(7955):333–5. PMID: 54740.54740
55 Tsurikisawa N, Saito A, Oshikata C, . Effective allergen avoidance for reducing exposure to house dust mite allergens and improving disease management in adult atopic asthmatics. J Asthma. 2016 Oct;53(8):843–53. Epub 2016 Apr 6. Also available: http://dx.doi.org/10.3109/02770903.2016.1155218. PMID: 27049597.27049597
56 Glasgow NJ, Ponsonby AL, Kemp A, . Feather bedding and childhood asthma associated with house dust mite sensitisation: a randomised controlled trial. Arch Dis Child. 2011 Jun;96(6):541–7. Also available: http://dx.doi.org/10.1136/adc.2010.189696. PMID: 21451166.21451166
57 Nambu M, Shirai H, Sakaguchi M, . Effect of house dust mite-free pillow on clinical course of asthma and IgE level -- a randomized, double-blind, controlled study. Pediatr Asthma Allergy Immunol. 2008 Sep;21(3):137–44.
58 Lee IS. Effect of bedding control on amount of house dust mite allergens, asthma symptoms, and peak expiratory flow rate. Yonsei Med J. 2003 Apr 30;44(2):313–22. PMID: 12728474.12728474
59 Rabito FA, Carlson JC, He H, . A single intervention for cockroach control reduces cockroach exposure and asthma morbidity in children. J Allergy Clin Immunol. 2017 Jan 10;S0091–6749(16):31349–5. [Epub ahead of print]. Also available: http://dx.doi.org/10.1016/j.jaci.2016.10.019. PMID: 28108117.28108117
60 Levy JI, Brugge D, Peters JL, . A community-based participatory research study of multifaceted in-home environmental interventions for pediatric asthmatics in public housing. Soc Sci Med. 2006 Oct;63(8):2191–203. Also available: http://dx.doi.org/10.1016/j.socscimed.2006.05.006. PMID: 16781807.16781807
61 Shirai T, Matsui T, Suzuki K, . Effect of pet removal on pet allergic asthma. Chest. 2005 May;127(5):1565–71. PMID: 15888829.15888829
62 Barnes CS, Kennedy K, Gard L, . The impact of home cleaning on quality of life for homes with asthmatic children. Allergy Asthma Proc. 2008 Mar–Apr;29(2):197–204. Also available: http://dx.doi.org/10.2500/aap.2008.29.3099. PMID: 18336723.18336723
63 Matsui EC, Perzanowski M, Peng RD, . Effect of an integrated pest management intervention on asthma symptoms among mouse-sensitized children and adolescents with asthma: a randomized clinical trial. JAMA. 2017 Mar 14;317(10):1027–36. Also available: http://dx.doi.org/10.1001/jama.2016.21048. PMID: 28264080.28264080
64 DiMango E, Serebrisky D, Narula S, . Individualized household allergen intervention lowers allergen level but not asthma medication use: a randomized controlled trial. J Allergy Clin Immunol Pract. 2016 Jul–Aug;4(4):671–679.e4. Also available: http://dx.doi.org/10.1016/j.jaip.2016.01.016. PMID: 27025297.27025297
65 Parker EA, Israel BA, Robins TG, . Evaluation of community action against asthma: a community health worker intervention to improve children’s asthma-related health by reducing household environmental triggers for asthma. Health Educ Behav. 2008 Jun;35(3):376–95. Also available: http://dx.doi.org/10.1177/1090198106290622. PMID: 17761540.17761540
66 Krieger JW, Takaro TK, Song L, . The Seattle-King County Healthy Homes Project: a randomized, controlled trial of a community health worker intervention to decrease exposure to indoor asthma triggers. Am J Public Health. 2005 Apr;95(4):652–9. Also available: http://dx.doi.org/10.2105/AJPH.2004.042994. PMID: 15798126.15798126
67 Morgan WJ, Crain EF, Gruchalla RS, . Results of a home-based environmental intervention among urban children with asthma. N Engl J Med. 2004 Sep 9;351(11):1068–80. Also available: http://dx.doi.org/10.1056/NEJMoa032097. PMID: 15356304.15356304
68 Krieger J, Takaro TK, Song L, . A randomized controlled trial of asthma self-management support comparing clinic-based nurses and in-home community health workers: the Seattle-King County Healthy Homes II Project. Arch Pediatr Adolesc Med. 2009 Feb;163(2):141–9. Also available: http://dx.doi.org/10.1001/archpediatrics.2008.532. PMID: 19188646.19188646
69 Bryant-Stephens T, Kurian C, Guo R, . Impact of a household environmental intervention delivered by lay health workers on asthma symptom control in urban, disadvantaged children with asthma. Am J Public Health. 2009 Nov;(99 Suppl 3):S657–65. PMID: 19890172.19890172
70 Bryant-Stephens T, Li Y. Outcomes of a home-based environmental remediation for urban children with asthma. J Natl Med Assoc. 2008 Mar;100(3):306–16. PMID: 18390024.18390024
71 Williams SG, Brown CM, Falter KH, . Does a multifaceted environmental intervention alter the impact of asthma on inner-city children? J Natl Med Assoc. 2006 Feb;98(2):249–60. PMID: 16708511.16708511
72 Walshaw MJ, Evans CC. Allergen avoidance in house dust mite sensitive adult asthma. QJM. 1986;58(226):199–215. PMID: 3520626.3520626
73 Hayden ML, Perzanowski M, Matheson L, . Dust mite allergen avoidance in the treatment of hospitalized children with asthma. Ann Allergy Asthma Immunol. 1997;79(5):437–42. PMID: 9396978.9396978
74 Cloosterman SG, Schermer TR, Bijl-Hofland ID, . Effects of house dust mite avoidance measures on Der p 1 concentrations and clinical condition of mild adult house dust mite-allergic asthmatic patients, using no inhaled steroids. Clin Exp Allergy. 1999;29(10):1336–46. Also available: http://dx.doi.org/10.1046/j.1365-2222.1999.00627.x. PMID: 10520054.10520054
75 Shapiro GG, Wighton TG, Chinn T, . House dust mite avoidance for children with asthma in homes of low- income families. J Allergy Clin Immunol. 1999;103(6):1069–74. Also available: http://dx.doi.org/10.1016/S0091-6749(99)70181-8. PMID: 10359888.10359888
76 Carswell F, Birmingham K, Oliver J, . The respiratory effects of reduction of mite allergen in the bedrooms of asthmatic children - a double-blind controlled trial. Clin Exp Allergy. 1996;26(4):386–96. Also available: http://dx.doi.org/10.1111/j.1365-2222.1996.tb00554.x. PMID: 8732235.8732235
77 Marks GB, Tovey ER, Green W, . House dust mite allergen avoidance: a randomized controlled trial of surface chemical treatment and encasement of bedding. Clin Exp Allergy. 1994;24(11):1078–83. Also available: http://dx.doi.org/10.1111/j.1365-2222.1994.tb02746.x. PMID: 7677828.7677828
78 Eggleston PA, Butz A, Rand C, . Home environmental intervention in inner-city asthma: a randomized controlled clinical trial. Ann Allergy Asthma Immunol. 2005 Dec;95(6):518–24. PMID: 16400889.16400889
79 Carter MC, Perzanowski MS, Raymond A, . Home intervention in the treatment of asthma among inner-city children. J Allergy Clin Immunol. 2001;108(5):732–7. Also available: http://dx.doi.org/10.1067/mai.2001.119155. PMID: 11692097.11692097
80 Korsgaard J. Preventive measures in mite asthma. A controlled trial. Allergy. 1983 Feb;38(2):93–102. PMID: 6342456.6342456
81 Warner JA, Frederick JM, Bryant TN, . Mechanical ventilation and high-efficiency vacuum cleaning: a combined strategy of mite and mite allergen reduction in the control of mite-sensitive asthma. J Allergy Clin Immunol. 2000;105(1):75–82. PMID: 10629456.10629456
82 Burr ML, Matthews IP, Arthur RA, . Effects on patients with asthma of eradicating visible indoor mould: a randomised controlled trial. Thorax. 2007 Sep;62(9):767–72. Also available: http://dx.doi.org/10.1136/thx.2006.070847. PMID: 17389753.17389753
83 Kercsmar CM, Dearborn DG, Schluchter M, . Reduction in asthma morbidity in children as a result of home remediation aimed at moisture sources. Environ Health Perspect. 2006 Oct;114(10):1574–80. Also available: http://dx.doi.org/10.1289/ehp.8742. PMID: 17035145.17035145
84 Htut T, Higenbottam TW, Gill GW, . Eradication of house dust mite from homes of atopic asthmatic subjects: a double-blind trial. J Allergy Clin Immunol. 2001;107(1):55–60. Also available: http://dx.doi.org/10.1067/mai.2001.111240. PMID: 11149991.11149991
85 Burr ML, Dean BV, Merrett TG, . Effects of anti-mite measures on children with mite-sensitive asthma: a controlled trial. Thorax. 1980 Jul;35(7):506–12. PMID: 7001667.7001667
86 Evans R III, Gergen PJ, Mitchell H, . A randomized clinical trial to reduce asthma morbidity among inner-city children: results of the National Cooperative Inner-City Asthma Study. J Pediatr. 1999 Sep;135(3):332–8. PMID: 10484799.10484799
87 El-Ghitany EM, El-Salam MM. Environmental intervention for house dust mite control in childhood bronchial asthma. Environ Health Prevent Med. 2012 Sep;17(5):377–84. Also available: http://dx.doi.org/10.1007/s12199-011-0263-5. PMID: 22302565.22302565
88 Breysse J, Dixon S, Gregory J, . Effect of weatherization combined with community health worker in-home education on asthma control. Am J Public Health. 2014 Jan;104(1):e57. Also available: http://dx.doi.org/10.2105/AJPH.2013.301402.
89 Takaro TK, Krieger J, Song L, . The Breathe-Easy Home: the impact of asthma-friendly home construction on clinical outcomes and trigger exposure. Am J Public Health. 2011 Jan;101(1):55–62. PMID: 21148715.21148715
90 Shani Z, Scott RG, Schofield LS, . Effect of a home intervention program on pediatric asthma in an environmental justice community. Health Promot Pract. 2015 Mar;16(2):291–8. Also available: http://dx.doi.org/10.1177/1524839914529593. PMID: 24733733.24733733
91 Turcotte DA, Alker H, Chaves E, . Healthy homes: in-home environmental asthma intervention in a diverse urban community. Am J Public Health. 2014 Apr;104(4):665–71. Also available: http://dx.doi.org/10.2105/AJPH.2013.301695. PMID: 24524511.24524511
92 Sweet L, Polivka BJ, Chaudry RV, . The impact of an urban home-based intervention program on asthma outcomes in children. Public Health Nurs. 2014 May;31(3):243–53. Also available: http://dx.doi.org/10.1111/phn.12071.24720657
93 Guise JM, Chang C, Viswanathan M, . Agency for Healthcare Research and Quality Evidence-based Practice Center methods for systematically reviewing complex multicomponent health care interventions. J Clin Epidemiol. 2014 Nov;67(11):1181–91. Epub 2014 Oct 17. Also available: http://dx.doi.org/10.1016/j.jclinepi.2014.06.010. PMID: 25438663.25438663
94 Gotzsche PC, Johansen HK. House dust mite control measures for asthma. Cochrane Database Syst Rev. 2008;(2):CD001187 Also available: http://dx.doi.org/10.1002/14651858.CD001187.pub3. PMID: 18425868.18425868
95 Kilburn S, Lasserson TJ, McKean M. Pet allergen control measures for allergic asthma in children and adults. Cochrane Database Syst Rev. 2001;CD002989. PMID: 12535446.12535446
96 Krieger J, Jacobs DE, Ashley PJ, . Housing interventions and control of asthma-related indoor biologic agents: a review of the evidence. J Public Health Manag Pract. 2010 Sep–Oct;16(5 Suppl):S11–20. PMID: 20689369.20689369
97 Portnoy J, Miller JD, Williams PB, . Environmental assessment and exposure control of dust mites: a practice parameter. Ann Allergy Asthma Immunol. 2013 Dec;111(6):465–507. Also available: http://dx.doi.org/10.1016/j.anai.2013.09.018. PMID: 24267359.24267359
98 Portnoy J, Chew GL, Phipatanakul W, . Environmental assessment and exposure reduction of cockroaches: a practice parameter. J Allergy Clin Immunol. 2013 Oct;132(4):802–8.e1–25. Also available: http://dx.doi.org/10.1016/j.jaci.2013.04.061. PMID: 23938214.23938214
99 Phipatanakul W, Matsui E, Portnoy J, . Environmental assessment and exposure reduction of rodents: a practice parameter. Ann Allergy Asthma Immunol. 2012 Dec;109(6):375–87. Also available: http://dx.doi.org/10.1016/j.anai.2012.09.019. PMID: 23176873.23176873
100 Portnoy J, Kennedy K, Sublett J, . Environmental assessment and exposure control: a practice parameter--furry animals. Ann Allergy Asthma Immunol. 2012 Apr;108(4):223.e1–15. Also available: http://dx.doi.org/10.1016/j.anai.2012.02.015. PMID: 22469456.22469456