# Methods

## Protocol Development

The National Heart, Lung, and Blood Institute (NHLBI) nominated this topic, as described in the Introduction. We generated an analytic framework, a preliminary Key Question, and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, and settings).

A Technical Expert Panel (TEP) was convened for this report. The TEP consisted of nine scientists and clinicians, including individuals with expertise in the clinical management of pediatric and adult asthma, and implementation of environmental control interventions to reduce exposure to allergens in the home. TEP members participated in conference calls and discussions through email to review the scope, analytic framework, Key Question, and PICOTS and provided input on the information and categories included in the evidence tables and analysis. A list of the TEP members is included in the front matter of the report. The final protocol was posted on the Effective Health Care Web site on October 11, 2016. A full version of our protocol for this systematic review is available online (https://effectivehealthcare.ahrq.gov/ehc/products/643/2318/asthma-nonpharmacologic-treatment-protocol-161004.pdf),^9^ and is registered in PROSPERO (http://www.crd.york.ac.uk/PROSPERO), with the registration number CRD42017055547.^10^

Initially, the Key Question addressed in this report was intended for inclusion in a larger report on nonpharmacologic management of asthma. The scope of the broader report also examined the use of bronchial thermoplasty for patients with severe asthma. The larger report was divided into two distinct reports in response to peer review and public feedback about the draft report. However, the guidance provided by the TEP and the content included in the posted protocol reflect the larger scope of work as initially planned.

## Literature Search Strategy

### Search Strategy

Literature searches were performed by Medical Librarians at the Evidence-Based Practice Center Information Center and followed established systematic review protocols. Searches covered the literature published from database inception (dates vary, see Appendix A) through April 21, 2017.

We searched the following databases using controlled vocabulary and text words: Embase^®^ and MEDLINE^®^ (searched together on the Embase.com platform), PubMed^®^ (In Process citations), CINAHL^®^ (Cumulative Index to Nursing and Allied Health Literature), and the Cochrane Library.

We used text words to search gray literature sources and the Web sites of relevant organizations identified by the clinical experts on the project team. A complete list of the resources we searched is available in Appendix A.

Search resources, concepts, and strategies are available in Appendix A. Reference lists from systematic reviews and meta-analyses were reviewed and compared against our retrieved articles. If a systematic review contained references that appeared to meet our inclusion criteria, but had not been captured by our initial search results, the search strategy was refined to include these articles. Supplemental Evidence and Data for Systematic Reviews (formerly known as Scientific Information Packets) submitted by interested parties were also reviewed.

Literature screening was performed in duplicate using the database Distiller SR (Evidence Partners, Ottawa, Ontario, Canada). Literature search results were initially screened for relevancy. Relevant abstracts were screened against the inclusion and exclusion criteria in duplicate. Studies that appeared to meet the inclusion criteria were retrieved in full and screened again in duplicate against the inclusion and exclusion criteria. All disagreements were resolved by consensus discussion between the two original screeners.

### Inclusion and Exclusion Criteria

#### Publication Criteria

Included articles must have been published as full-length, peer-reviewed studies. Abstracts and meeting presentations were not included because they do not include sufficient details about experimental methods to permit an evaluation of study design and conduct; they may also contain only a subset of measured outcomes.^11,12^ Additionally, it is not uncommon for abstracts that are published as part of conference proceedings to have inconsistencies compared with the final study publication or to describe studies that are never published as full articles.^13–17^ To avoid double-counting patients, when several reports of the same or overlapping groups of patients were available, only outcome data from the report with the most patients were included. However, we included data from a smaller study when it either reported data on an outcome that the index report did not provide or when it provided longer followup data for a specific outcome.

When a study with an English abstract but published in a foreign language was identified, the abstract was assessed against the full set of inclusion/exclusion criteria. If the study appeared to fit the inclusion criteria, we evaluated whether excluding the study might result in language bias (e.g., if the findings differ from other included studies). If language bias seemed unlikely, we excluded the study.

### Study Selection

We followed the PICOTS (Table 1) framework in developing the criteria for study inclusion. We included studies of patients of any age with a diagnosis of asthma. We included studies of asthma and other allergic conditions, when ≥85 percent of enrolled patients had asthma or when outcomes were reported separately for the subgroup with asthma. Studies that did not report whether patients were sensitized or allergic to indoor allergens were included. Studies had to report on one or more of the outcomes prespecified in our PICOTS. Study inclusion was not restricted by language of publication or treatment duration. Randomized controlled trials (RCTs) and nonrandomized interventional studies with concurrent controls (e.g., nonrandomized trials) or historical controls (e.g., pre-post studies) were considered for inclusion. We excluded in vivo, in vitro, and animal studies.

Table 1 PICOTS (populations, interventions, comparisons, outcomes, timing, and setting) criteria for including studies in the review

Category | Criteria
Populations | - All severity of asthma; - Any age
Interventions | - [underlined: Acaricide (house dust mite pesticide)]; ○ Applied to carpet, mattresses, and/or furniture; - [underlined: Air quality]; ○ Air purifiers; ○ Ventilation or duct cleaning; - [underlined: Carpet]; ○ Removal; ○ Wall-to-wall versus area rugs; ○ Cleaning (professional services; high-efficiency particulate air-filtration (HEPA) vacuums); - [underlined: Linens and furniture]; ○ Pillow/mattress covers; ○ Furniture covers/”wipe-down” furniture; ○ Frequent laundering of linens; - [underlined: Mold removal]; - [underlined: Animals and insects]; ○ Pet bathing; ○ Pet removal or restriction of pet access; ○ Pest control (professional and lay interventions); - [underlined: Multicomponent interventions]; ○ Multiple strategies implemented concurrently
Comparators | - No intervention to reduce or eliminate exposure to indoor inhalant allergen(s); - Reduction or elimination of exposure to different indoor inhalant allergen(s); - Reduction or elimination of exposure to multiple indoor inhalant allergens
Outcomes | Primary Outcomes; - Asthma control; ○ Asthma Control Test (ACT)/Childhood ACT; ○ Asthma Control Questionnaire; - Exacerbations; ○ Systemic corticosteroids for asthma; ○ Asthma-specific hospitalizations; ○ Asthma-specific emergency department (ED) visits; ○ Asthma-specific urgent care visits (other than ED); ○ Asthma-specific admissions to intensive care unit or intubations; - Health care utilization and costs; ○ Asthma-specific ambulatory care visits; ○ Asthma-specific medication use (including medication name, dose, duration); ○ Hospitalizations, ED visits, urgent care visits; ■ All cause; ■ Associated with potentially asthma-related complications; □ Pneumonia; □ Myocardial infarction; □ Steroid-induced hyperglycemia; ○ Asthma-specific days missed from work or school; ○ Participation in sports and recreational activities; - Pulmonary physiology; ○ Peak expiratory flow; ○ Spirometry; ○ Airway hyper-responsiveness; - Quality of life; ○ Asthma Quality of Life Questionnaire; ○ Pediatric Asthma Quality of Life Questionnaire; ○ Pediatric Asthma Caregivers Asthma Quality of Life Questionnaire; - Death, asthma-specific, and all cause; Secondary Measures; - Patient-reported symptoms; - Indoor inhalant allergen levels measured by formal testing
Timing | Studies with all lengths of followup duration will be considered
Setting | - Home; - Work; - School; - Daycare

### Data Extraction

Data were abstracted using Microsoft Word. Duplicate abstraction on a 10-percent random sample was used to ensure accuracy. All discrepancies were resolved by consensus discussion among the two original abstracters and an additional third person as needed. Elements abstracted included general study characteristics, patient characteristics, details of interventions, outcomes data, and risk of bias items.

In accordance with the approach used by the Guidelines for the Diagnosis and Management of Asthma,^1^ we have defined “pediatric” or “child” populations as including patients age 11 or younger and “adult” populations as including youths age 12 or older and adults. Studies that include patients in both categories are described as having a “mixed population.”

## Risk of Bias Assessment of Individual Studies

We used the Cochrane Collaboration’s tool for assessing risk of bias in RCTs.^18^ Study characteristics were rated as introducing “low,” “high,” or “unclear” risk of bias. For nonrandomized studies, we used the Newcastle-Ottawa scale and rated study characteristics as “low,” “moderate,” “high,” or “unclear.”^19^ Risk of bias was assessed by two independent reviewers, and discrepancies were addressed through consensus discussion.

We considered the funding source of individual studies as presenting a potentially important risk of bias. Therefore, for any study that reported receiving all or part of its funding from, or was coauthored by one or more employees of, a commercial manufacturer of an intervention, we noted that information in the risk of bias tables. We also rated the “Other Sources of Bias” component in the Cochrane scale as “high” in cases in which study funding presented a potential conflict of interest.

We created a summary assessment of “overall risk of bias” for each study by grouping the criteria included in the Cochrane tool into four categories based on the nature of their respective threats to validity. The four categories address: 1) participant enrollment (comprising “sequence generation” and “allocation concealment”); 2) blinding (“blinding participants and personnel” and “blinding outcome assessors”; 3) outcome data (“incomplete outcome data” and “selective outcome reporting”); and 4) other sources of bias. We then concluded that an individual study was at “high” overall risk of bias if it was assigned a “high” risk rating for one or more discrete criteria in at least two different categories. A study was determined to be at “medium” overall risk of bias if it was assigned a “high” risk rating in only one discrete criterion or in two criteria within the same category. Therefore, if a study was at “high” risk of bias for both “sequence generation” and “incomplete outcome data,” the overall risk would be “high” because there is concern about two different categories. Conversely, if a study was at “high” risk of bias for “sequence generation” and “allocation concealment,” then the overall risk would be “medium” because the two criteria are in the same category. If no criteria were assessed to be at “high” risk, then the overall risk of bias was “low.” However, if we rated the risk as “unclear” in two or more categories, then the overall risk was “unclear.”

## Data Synthesis

Due to the heterogeneity of the included studies, we did not attempt to combine data from the studies quantitatively using meta-analyses. Additionally, some interventions were evaluated in only one study; thus, quantitative synthesis was not possible. Instead, we provide a narrative synthesis of the studies’ general findings.

For the multicomponent studies, we organized the data synthesis and analysis by grouping studies according to their active components. We defined the “active component” as an intervention that was implemented in the intervention arm but not the study’s control arm. Such interventions met inclusion criteria of this review, as shown in Table 1 above.

We have described outcomes as statistically significant when identified as such by the authors of the primary studies. Statistical significance, however, does not always equate with clinically significant changes in outcomes. In the strength of evidence (SOE) tables, we noted any cases in which a statistically significant result was not associated with an effect size that exceeded standard thresholds for clinical significance, as described in Appendix E; in the absence of published standards of minimal important differences, we identified outcomes that did not improve by an absolute difference of at least 10 percent (between groups or above baseline, depending on the comparison.)

SOE was assessed for the following validated outcomes: asthma-control measures, asthma-exacerbation measures, asthma-related health care utilization and costs, asthma-related pulmonary physiology, and asthma-related quality of life. Symptoms were included as an unvalidated secondary measure, and changes in allergen levels were reported as a measure of the effectiveness of the interventions.

## Strength of the Body of Evidence

We graded the SOE of each comparison and outcome based on the guidance established by the Evidence-Based Practice Center (EPC) program. This approach incorporates five key domains: study limitations, consistency, directness, precision, and reporting bias. Overall SOE was graded as “high,” “moderate,” “low,” or “insufficient.” Evidence based on RCTs was assigned an initial SOE of “high,” while evidence based on non-RCTs was assigned an initial SOE of “low.” The SOE was then downgraded as appropriate based on the five domains as described below.

We determined study limitations by appraising the degree to which the included studies for the given comparison and outcome had adequate protection against bias (i.e., has good internal validity). In general, we downgraded for study limitations when 50 percent or more of the studies evaluated for a given outcome were at “high” overall risk of bias as described above. When 50 percent or more of the studies were at “medium,” “low,” or “unclear” risk of bias, we did not downgrade for study limitations. If the evidence permits a conclusion, then, all else being equal, a set of studies at low risk of bias yields a higher SOE rating than a set of studies at high risk of bias.

We assessed consistency of results for the same outcome among the available studies in terms of the direction and magnitude of effect. In general, we downgraded for inconsistency when there was heterogeneity in the effects of an intervention across studies for a given outcome that could not be explained through identifiable differences in study characteristics. We downgraded for unknown consistency when only a single study was included for an outcome. In some cases, we downgraded the SOE by two levels for substantial inconsistency, when we were unable to reconcile evidence favoring an intervention with evidence suggesting no effect.

The evidence was considered indirect if the populations, interventions, comparisons, or outcomes used within studies did not directly correspond to the comparisons we were evaluating.

Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome and may be affected by sample size, number of events, and width of confidence intervals. In some cases, we downgraded the SOE by two levels due to substantial imprecision resulting from very small samples or numbers of events, or when it was not possible to assess an estimate of effect based on the available data (e.g., measures of variance were not included, or results were presented graphically without reporting of specific data points).

Reporting bias includes publication bias, outcome-reporting bias, and analysis reporting bias. Given the small number of studies we evaluated for most of the interventions (and the lack of effect for interventions that were more widely studied), we did not examine funnel plots. We downgraded for reporting bias when we detected a likelihood of outcome reporting bias (important clinical outcomes appear to have been collected but not reported by the studies within a comparison) or analysis reporting bias (important comparisons were not analyzed). For studies that had commercial funding and/or authorship, we also assessed the size and direction of any effect compared to the studies that did not receive commercial support, to identify possible publication or reporting bias.

Please note that the SOE synthesis approach enables reviewers to assess each individual component (i.e., study limitations, consistency, etc.) and then use their judgment to produce an overall SOE rating that represents a global assessment. Although the SOE domains are reported categorically, they represent concepts that are evaluated and integrated on a continuum. The final SOE assessment must be consistent with the domains, but they also reflect the interaction between components, the robustness of the findings, and the reviewer’s confidence in the full body of evidence. Therefore, any two outcomes may have similar or identical limitations (such as inconsistency and imprecision) and nevertheless have different overall assessments.

## Applicability

Several a priori factors may limit the applicability of findings. Many studies included children under age 11, youths age 12 or older, and adults, making it difficult to apply the findings to a single age group. Studies also often focused on patients at high risk for exposure to allergens, and this may not represent the general asthma population. Another important consideration is that many patients with asthma in the “real world” may have limited opportunities to implement some of the interventions examined in this report, such as structural changes like carpet removal.

## Peer Review and Public Commentary

Experts in clinical management of asthma and strategies to minimize the presence and effect of indoor inhalant allergens were invited to provide external peer review of the draft report. AHRQ staff, an Associate Editor, and representatives from NHLBI reviewed the draft report before it was distributed for peer review. The draft report was also posted on the Agency for Healthcare Research and Quality (AHRQ) Web site from April 26, 2017, to May 25, 2017, for public comment. We revised the report based on peer and public feedback and noted these revisions in the Disposition of Comments Report. The disposition report is made available 3 months after the final review is posted on AHRQ’s Web site.

Several important revisions were made to the report in response to peer review and public comment. First, as noted above, this review was initially designed to include the current Key Question as well as an additional Key Question addressing the effectiveness of bronchial thermoplasty. We separated the larger review into two independent reports in response to substantial feedback. Second, we expanded the Discussion chapter to address in greater depth some of the major limitations and contextual factors that are important for interpreting this evidence base. These issues include the distinction between patient sensitization to an allergen and actual allergic reaction; lack of established thresholds for determining clinically meaningful improvement for many of the primary and secondary outcome measures we evaluated; exposure to allergens outside a patient’s home (especially at school, work, or other routine activities); and the key difference between a lack of evidence (i.e., few or no high-quality published studies addressing a question) and a lack of efficacy (i.e., evidence that an intervention was tested and did not improve outcomes). We also explored in more detail how our methods and findings compared with and differed from previous influential reviews and guidelines. Finally, in response to peer and public commentary as well as feedback from AHRQ staff, we conducted a Qualitative Comparative Analysis of the studies to provide additional insight into the multicomponent interventions.

## Qualitative Comparative Analysis

We used qualitative comparative analysis (QCA) to further evaluate the studies. QCA uses formal logic to examine combinations of “conditions,” such as the different strategies within multicomponent interventions, and assesses their relationship to important outcomes.^20–23^ Single interventions or combinations of strategies can be evaluated simultaneously. Conditions may be determined to be necessary, sufficient, or both for a given outcome. A necessary condition must be present for an outcome to occur, but it might not guarantee the outcome if other conditions are also necessary. A sufficient condition ensures the outcome will occur; however, it may not always be necessary if more than one strategy or set of strategies is capable of achieving the outcome.

QCA uses formal logic and set theory rather than statistical theory and thus does not identify statistical associations. Rather, QCA helps identify various combinations of factors, or “recipes,” that may yield a specific result. The QCA approach is designed to provide one or more “solutions,” which are combinations of conditions that are necessary, sufficient, or both for a particular outcome. This analytic technique was incorporated into our review to determine whether specific bundles of allergen reduction interventions may be more likely to improve asthma outcomes. Strength of evidence assessment was not performed for the QCA results.

Specific analytic steps are described in Appendix D.