# Introduction

## Background

Asthma is a chronic inflammatory disorder of the airways, characterized by varying degrees of airflow obstruction. Bronchoconstriction, inflammatory cell infiltration, and airway edema reduce airflow intermittently, often in response to specific exposures, resulting in respiratory symptoms.^1^ In the United States, asthma’s prevalence has increased over the past decade, from an estimated 22.2 million Americans in 2005 to 24 million Americans in 2014.^2,3^ Asthma can significantly affect patients’ and families’ quality of life and ability to pursue activities such as school, work, and exercise. Globally, asthma ranks 14th based on the burden of disease, as measured by disability-adjusted life years.^4^ In the United States, asthma contributes significantly to health care resource utilization and associated costs. For example, in 2012, asthma was one of the top 20 leading diagnosis groups for primary care visits and was the main reason for 1.8 million emergency department visits and 439,000 hospitalizations. While the severity of disease varies between patients and over time in the same patient, asthma can be fatal, accounting for approximately 1 death per 100,000 Americans.^5^

### Effectiveness of Indoor Inhalant Allergen Reduction

Control of environmental factors that may contribute to asthma is one of the four components of asthma management. Many common indoor inhalant allergens have been associated with increased risk of asthma exacerbations, including animal dander, house dust mites (HDMs), mice, cockroaches, and mold.^6^ Numerous interventions have been designed to reduce exposure to allergens in the environment where patients with asthma live, work, learn, play, and sleep.^7^ These interventions include use of acaricides (HDM pesticides), air purification systems, carpet removal or vacuuming, use of specially designed mattress covers and pillowcases, mold removal, pest control techniques, and containment or removal of family pets.

Evaluating the effectiveness of allergen exposure reduction interventions presents multiple challenges. Strategies to control environmental factors often include multicomponent approaches, which incorporate at least two different interventions resulting in difficulty identifying the effectiveness of individual component interventions. Moreover, a “single” intervention (e.g., vacuuming) may be expected to reduce or eradicate exposure to multiple allergens simultaneously and the effects on specific allergens may differ as a consequence of the same intervention. Other challenges in interpreting the literature include heterogeneity in the populations studied (e.g., documentation of sensitization to the targeted allergen, asthma severity and control) and inadequate descriptions of the interventions (e.g., lack of specificity with respect to the device used for air filtration, or compliance with use, or whether changes in allergen exposure were documented).

### Purpose of the Systematic Review

In 1989, the National Heart, Lung, and Blood Institute (NHLBI) initiated the National Asthma Education and Prevention Program (NAEPP) to address growing concern about asthma in the United States. One of NAEPP’s first accomplishments was to convene a panel of experts that produced a report in 1991, The National Asthma Education and Prevention Program Expert Panel Report (EPR): Guidelines for the Diagnosis and Management of Asthma. The guidelines address the diagnosis, evaluation, and treatment of asthma. Given that the most recent report, EPR-3, was published in 2007,^1^ NHLBI assessed the need for an update by requesting information from the public, NAEPP Coordinating Committee Members and its affiliates, and members of the 2007 Expert Panel. Collected information was provided to the NHLBI Advisory Council Asthma Expert Working Group, which produced a report to summarize the process and recommendations from their needs assessment.^8^ The Working Group identified six high-priority topics that should be updated. For each topic, Key Questions meriting a systematic literature review were formulated. NHLBI engaged the Agency for Healthcare Research and Quality to perform the systematic reviews through its Evidence-Based Practice Centers. This document represents the systematic review of “The Effectiveness of Indoor Allergen Reduction in the Management of Asthma.” The review also highlights areas of controversy and identifies needs for future research on this priority area.

## Scope and Key Question

This report’s main objective is to conduct a systematic review of the benefits and harms of interventions to reduce indoor inhalant allergens for the management of asthma in adults and children. In this review, we address the following Key Question:

Key Question Among individuals with asthma, what is the effectiveness of interventions to reduce or remove exposures to indoor inhalant allergens on asthma control, exacerbations, quality of life, and other relevant outcomes?

## Analytic Framework

We developed an analytic framework to guide the systematic review process (Figure 1).

Figure 1 Analytic framework for indoor allergen reduction in the management of asthma

KQ=Key Question

Dashed line indicates theoretical relationship

Figure 1 depicts the Key Question within the context of the PICOTS described above. The figure illustrates how reducing exposure to indoor allergens for adults and children with asthma affects the intermediate outcome of indoor allergen levels, shown in the oval in the middle of the figure. Ultimately, the figure depicts the long-term results of allergen control, which are listed in the box on the right. Primary outcomes include: asthma control, asthma exacerbations, asthma-related healthcare utilization and costs, pulmonary physiology, asthma-related quality of life, and death. Asthma symptoms are included as a secondary outcome.

## Organization of This Report

In the remaining three chapters of this report, we describe the methods for this systematic review, present the results, and discuss the overall findings. Within the Results chapter, we provide the results of the literature searches and screening procedures, as well as descriptions of included studies, key points, detailed syntheses of the studies, and strength-of-evidence tables. The Discussion chapter reviews the key findings and strength of evidence, places the findings in the context of previous systematic reviews, examines the general applicability of the studies, discusses implications for decisionmaking, describes limitations of the systematic review process and the evidence base, and identifies knowledge gaps that require further research.

A list of acronyms and abbreviations appears after the references, followed by five appendixes: Appendix A. Search Strategies; Appendix B. Excluded Studies; Appendix C. Evidence Tables; Appendix D. Qualitative Comparative Analysis; and Appendix E. Minimally Important Differences.