# Key Messages

## Purpose of Review

To evaluate the effectiveness of indoor allergen reduction interventions on asthma outcomes.

## Key Messages

- Evidence for single interventions designed to reduce indoor allergen exposure on asthma outcomes is lacking.
- Multicomponent interventions that bundle more than one strategy may improve some asthma outcomes, but it is unclear if specific combinations are more effective than others.
- Multicomponent interventions that include high-efficiency particulate air-filtration (HEPA) vacuums or pest control reduce exacerbations and improve quality of life.
- The evidence for both single and multicomponent interventions does not address many other important outcomes, including asthma-related health care utilization, pulmonary physiology, and asthma-related quality of life.