# Discussion

## Key Findings and Strength of Evidence

We identified 60 randomized controlled trials (RCTs) and 8 additional studies (4 nonrandomized trials and 4 pre-post studies) that examined 8 types of interventions, alone or in combination, to reduce allergen levels in the home and improve the wellbeing of patients with asthma. Thirty-eight studies evaluated isolated interventions, and 30 studies used multicomponent strategies. Thirty-six studies enrolled patients above and below the age of 12, while 22 studies were limited to patients over 12 years old, and 9 studies were limited to patients less than 12 years old. Forty RCTs confirmed that all of their enrolled patients were sensitized to an allergen that was targeted by their intervention, and an additional 14 studies reported that a majority of patients were sensitized. Sensitization was confirmed through skin- prick testing in 43 of the 60 RCTs.

Seven studies examined the use of acaricide as the sole intervention designed to eliminate house dust mite (HDM) allergens. The evidence found no improvement in pulmonary physiology when comparing acaricide with placebo (strength of evidence [SOE]: moderate) or with other interventions (SOE: low), and other outcomes were inconclusive or not reported. Six multicomponent studies included acaricide and provide evidence suggesting no improvement in pulmonary physiology (SOE: moderate), while other primary outcomes were inconclusive or not reported. These multicomponent studies also found no improvement in the secondary outcome of asthma symptoms (SOE: high). However, acaricides were shown to reduce the secondary outcome of HDM allergen burden (SOE: low).

Nine studies evaluated the use of air purification as a single intervention. The evidence for asthma control and pulmonary physiology measures was inconclusive, while health care utilization was unchanged (SOE: low) and quality of life improved (SOE: low). Five additional studies included air purifiers within multicomponent strategies and observed no improvement in asthma control (SOE: low), exacerbations (SOE: high), or quality of life (SOE: high). However, school absenteeism was reduced (SOE: low). The secondary measures of asthma symptoms improved (SOE: low), and allergen levels were reduced (SOE: moderate).

No studies looked solely at removal of carpeting as an intervention. Eight multicomponent studies encouraged participants to remove carpets from their homes, but we could not determine from the studies how many patients actually removed carpeting or from which rooms. Evidence from these studies is inconclusive for clinical outcomes, although significant reduction in the secondary outcome of allergen levels was observed (SOE: moderate).

One small study examined high-efficiency particulate air-filtration (HEPA) vacuums alone, but the evidence base is insufficient to draw conclusions. Eight multicomponent studies included HEPA vacuums along with other strategies. The evidence was insufficient for asthma control and pulmonary physiology measures. Exacerbations were reduced (SOE: moderate) although medication use was unchanged (SOE: high), and no effect was seen for school absenteeism (SOE: low) or work absenteeism (SOE: moderate). Quality of life was improved among children (SOE: moderate). In addition, the multicomponent studies found that secondary measures of asthma symptoms improved among children (SOE: low) but not among mixed populations (SOE: low).

Seventeen studies focused on impermeable mattress covers or other approaches designed to limit HDM allergens on bedding. The evidence suggests no difference in exacerbations, health care utilization, pulmonary physiology, or quality of life (SOE: high), although these studies suggest that the presence of HDM allergen was reduced significantly (SOE: moderate). Mattress covers were also used in 19 multicomponent intervention studies. In these studies, covers were associated with reduced school absenteeism and fewer missed activities (SOE: low), but no improvement was identified for emergency department use (SOE: low), hospitalizations (SOE: high), acute care visits (SOE: moderate), pulmonary physiology (SOE: high), or quality of life (SOE: moderate). Evidence was mixed for the secondary measure of asthma symptoms, with no difference detected for composite measures (SOE: high), but a reduction in symptomatic days was observed (SOE: high). Finally, allergen levels were reduced in the multicomponent studies that included mattress covers (SOE: low).

The single-intervention studies did not address mold removal, but six multicomponent studies did feature it. Secondary measures of asthma symptoms improved (SOE: low), but other outcomes were inconclusive.

One nonrandomized study used pest-control strategies alone. The findings of this study were insufficient to draw any conclusions. Thirteen multicomponent studies included pest-control efforts. The evidence was inconclusive for asthma control, pulmonary physiology measures, and medication use. Exacerbations were reduced when measured as a composite score (SOE: high), but no effect was observed when individual measures such as emergency department visits (SOE: moderate) and hospitalizations (SOE: high) were examined. Quality of life among children (SOE: low) was improved, and school absenteeism was reduced (SOE: low). The secondary outcome of asthma symptoms also showed improvement (SOE: low), and allergen levels were reduced (SOE: low).

One nonrandomized study examined pet removal as a single strategy. The evidence was inconclusive for exacerbations and health care utilization, and no other outcomes were reported. Two multicomponent interventions also included pet removal, but we did not evaluate the SOE because of the small number of studies.

One important factor in assessing the effectiveness of interventions is the role of the intermediate outcome of allergen reduction as measured on home surfaces. In the studies of single interventions, we found that evidence for allergen reduction was generally consistent with evidence for the primary clinical outcomes. Specifically, the evidence for primary outcomes was either inconclusive or showed low SOE for no effect, and our conclusions for the allergen reduction outcomes were similar. The only exception was the evidence for mattress covers. When mattress covers were used, we found moderate-strength evidence demonstrating significant reduction of allergen levels; however, this did not result in a corresponding improvement in the primary clinical outcomes, for which we found high- or moderate-strength evidence for no effect.

Within the studies of multicomponent interventions, 10 trials found that allergen reduction outcomes were consistent with primary outcomes, sharing either significant improvement or no change. Five studies, however, reported decreased allergen levels that did not lead to better clinical results, and no individual studies showed improved primary outcomes without reduced allergen levels. Unfortunately, half of the multicomponent intervention studies did not report the data needed to evaluate the interaction between allergen levels and patient outcomes.

Evaluation of the studies with qualitative comparative analysis (QCA) reinforces these findings. We developed a simplified model and used a low threshold for defining positive results, but nevertheless did not identify any single intervention of bundle of strategies that appears to reliably result in better outcomes for patients with asthma. The only empirically plausible solution we derived includes a combination of pest control with use of a HEPA vacuum, but the solution is based on three studies that are heterogeneous in other ways. Evaluation of the published studies with QCA thus confirms that we lack strong evidence about the effectiveness of allergen reduction interventions.

## Findings in Relation to What Is Already Known

These findings are generally consistent with previous Cochrane reviews. In 2011, Gotzsche and Johansen updated their Cochrane systematic review of strategies for controlling house dust mite (HDM) exposure, including mattress covers and acaricides.^94^ Similar to our review, the authors found that these interventions were not associated with significant clinical effects, and they characterized the overall evidence base as lacking necessary rigor. In 2009, Kilburn and colleagues published a Cochrane review of air-filtration devices for reducing pet allergens.^95^ They identified only two relevant studies, and neither demonstrated clinical benefit. The authors concluded that the evidence base was insufficient to draw any conclusions.

In contrast to our findings, a 2010 systematic review by Krieger et al. examined most of the same intervention types addressed in our review and found the evidence for some strategies to be compelling.^96^ They conclude that multicomponent interventions that are tailored to a patient or family are effective. Their review also found that pest control and strategies to reduce moisture and mold were effective in reducing both mold and allergy symptoms. Although their review examined many of the same studies included in our current review, unlike our review, their review emphasized different outcomes, such as evidence suggesting reduced allergen levels on mattresses, floors, and carpets. In addition, they did not use a formal approach in their review of the evidence (such as the Evidence-based Practice Center (EPC) approach), and instead used a less formal approach incorporating expert opinion and epidemiologic evidence drawn from noninterventional studies. Likely because of these methodological differences, Krieger et al. concluded that individual interventions demonstrate consistent clinical benefits, while our review demonstrates limited strength of evidence based on the heterogeneity and inconsistent results among the studies that we evaluated.

Similarly, methodological differences in our respective approaches likely results in conclusions that vary from the review that was used to support the 2007 guidelines of the National Heart, Lung, and Blood Institute (NHLBI)^1^ as well as clinical practice parameters published by the American Academy of Allergy, Asthma, and Immunology.^97–100^ Whereas the prior review for the preparation of EPR-3 suggested there was greater benefit for the interventions intended to reduce exposure to allergens, our review identified deficits in the evidence base with low or insufficient strength of evidence (SOE). Our review differed in the studies included, with some publications after 2007 detecting no clinical effects of the interventions. In addition, our focus was intentionally restricted to studies with data on validated, clinical outcome measures, and we used alternative methods to assess the risk of bias, which also influenced the SOE ratings. Most importantly, we used the EPC approach to evaluate the evidence base, and our conclusions were therefore shaped by a methodology that was not used in the reviews that informed the earlier guidelines. These differences may account for variations between our assessment of the evidence and the preceding reviews.

## Applicability

There was substantial variability in patients’ baseline clinical characteristics suggesting that patients were not equally likely to benefit from the interventions we reviewed. Although sensitization to common indoor inhalant allergens was measured in most studies we evaluated, sensitization is a proxy measure that does not perfectly predict whether a patient will have an allergic reaction when exposed under real-world conditions, nor does sensitization precisely identify the severity of a potential reaction. Therefore, although 40 of 60 randomized controlled trials (RCTs) reported that all enrolled patients were sensitized to at least 1 allergen, and an additional 14 trials reported that a majority of patients were sensitized, none of these studies identified how many patients exhibited signs or symptoms of allergic reaction. Moreover, variation in how sensitization is measured is an important related factor. Skin-prick testing is considered the most accurate method for assessing sensitization; 43 studies used this method. However, 13 studies measured sensitization using blood tests, which are viewed as a less reliable predictor of true allergy. Some patients in these studies were probably not actively allergic and therefore unlikely to benefit from the interventions. Inclusion of these patients may help explain the lack of effect observed across the evidence base. Due to these challenges in assessing the allergic status of patients included in clinical studies, we are limited in our ability to assess the applicability of the overall evidence base to real-world patients with asthma.

In addition to the potential utility of documenting sensitization status to characterize patients with asthma in these clinical studies, the generalizability of the findings is also likely affected by disease severity. Based on the outcomes defined in Table 1, we expect that underlying asthma severity influenced our ability to detect a treatment effect. For example, if patients with mild asthma are unlikely to have an exacerbation within any given 12–24 week period (even without treatment), then assessing the effect of allergen removal (versus no intervention) on exacerbations will not show a difference between the groups (because no one has exacerbations) even if the allergen removal is effective. In our review, only 18 RCTs classified the severity of participants’ asthma: 11 studies included patients with moderate to severe asthma, 5 studies included patients with mild to moderate asthma, and 2 studies had populations with mixed severity. More importantly, 42 studies did not report asthma severity when characterizing the patient population. Therefore, it is possible that the results were affected by asthma severity (e.g., no effects were shown in patients with mild disease) and in most studies we have no information on disease severity to assess the impact of asthma severity on our conclusions. Similarly, we cannot draw conclusions regarding which patients are most likely to respond to allergen removal interventions based on disease severity or how long after the allergen removal clinical effects should be seen in the absence of consistent data.

A third major factor is the age of patients with asthma. Current clinical guidelines organize treatment recommendations along an age continuum in which “children” are identified as patients age 11 or younger, while youths 12 year of age or older are combined with adults. However, 33 studies we reviewed include patients from both groups. This is often due to studies enrolling populations that would, in other clinical contexts, be considered “pediatric” or “adolescent” (e.g., enrolling patients age 5 to 15 years old). It is therefore challenging to apply the results of studies in these “mixed” populations to the discrete categories of “child” or “adult.” Given the limited robustness of most study results, however, it is unclear whether better alignment between study population age cohorts and treatment categories would result in different overall findings.

The applicability of our findings is also limited by the type of interventions we assessed. One important consideration is the challenge of implementing home-based interventions properly and completely. Many of the interventions we reviewed may be difficult for families to implement due to cost, language, technology, home ownership, and health literacy. Socioeconomic status can also play a role in implementation, as can the type of living unit (e.g., house or apartment, attached or detached, single family or multifamily). Nearly half of the multicomponent intervention studies, 13 of 30, included a community health worker who received specialized training to educate patients on how to reduce home allergen exposure in a highly tailored way. Although we did not evaluate the direct impact of these health workers because they have traditionally focused on patient education activities, their role in the process of implementing home-based strategies may be important.

Similarly, it is difficult to measure fidelity to proper use of a home-based intervention. Although several studies reported that adherence to study protocols was evaluated periodically (through surveys or home visits), most studies did not report these findings or discuss these challenges. In clinical practice, it is likely difficult to assess how successfully a patient adheres to use of an allergen-reduction strategy.

Another important factor is the potential exposure to indoor allergens outside the home. Patients with asthma may be exposed to allergens at work or school or while engaged in other activities. Such exposure may limit the effectiveness of interventions that are implemented only at home. This review was designed to include studies that evaluated interventions in work or school environments, but we did not identify any studies that fit those criteria.

An additional consideration is the role that exposure to outdoor allergens or non-allergen irritants may have on asthma outcomes. Inhalation of tobacco smoke, other pollutants, pollen, or microbes may trigger morbidity for patients with asthma and reduce the overall effectiveness of targeted interventions.

Finally, a major factor to consider is the distinction between single interventions that address a single allergen (e.g., acaricide for HDM allergen), single interventions that address multiple allergens (e.g., air purifiers), and multicomponent interventions that usually target more than one allergen. Since patients vary in their sensitization to different allergens, the interplay between allergen type, intervention type, and individual patient characteristics may strongly modify the effect of these interventions.

When considering the control or comparison conditions, a further limitation is the inherent difficulty in evaluating the relationship between individual interventions within a multicomponent strategy. Multicomponent studies represent nearly half of the evidence base, but interpretation of their results is challenging. Since we were unable to identify specific “bundles” of interventions, or detect patterns among the studies that reported positive results, our analytic approach focused on assessing active components separately. This strategy may under- or over-emphasize the role of specific interventions, and overlook the importance of their interaction. The evidence base is also limited by a lack of head-to-head comparisons between interventions. Almost all the studies we assessed compared a single intervention or a bundle of interventions with either a placebo group or no intervention. We are therefore unable to assess whether a particular intervention may be more effective than another active intervention.

With respect to outcomes, very few studies reported critical, discrete, validated outcome measures, which have established thresholds for clinical significance such as Asthma Control Test (ACT) or Asthma Quality of Life Questionnaire [AQLQ] (see Appendix E). While many studies reported data for forced expiratory volume in one second (FEV_1_) or rescue medication use, they varied in their reporting, limiting meaningful comparisons across trials. Other studies employed composite metrics (e.g., a global measure of hospitalizations, emergency department visits, and urgent care visits). The relative paucity of studies using current, standardized measures limited our interpretation of the primary outcome measures.

Some of the validated, clinically important outcomes we used for our review also take an extended observation period to detect a change; whereas asthma symptoms may change in a matter of days in response to an intervention, lung function or health care utilization may take several months before the effect of removing an allergen is observed. Treatment duration in the included studies ranged from 4 weeks to 3.5 years, with most studies falling within the range of 6 to 12 months. As maintaining an allergen-reduction strategy over time, particularly a multicomponent intervention, is challenging, studies employing short treatment times may not be reflective of real-world use of these interventions.

There was a high level of heterogeneity across studies, particularly related to patient characteristics and the combinations of treatments examined, that limited our ability to assess generalizability to the overall population of people with asthma.

## Implications for Clinical and Policy Decisionmaking

This review highlights several important considerations for patients, clinicians, and policymakers. Since asthma can significantly affect overall health and quality of life, patients and their families may be motivated to adopt interventions that are not physically invasive, such as use of mattress covers or air purifiers, to augment pharmacologic treatment. It is important for clinicians to consider the complexity of the patient population and the limitations of the evidence that we have identified. Clinicians may also find it helpful to consider the severity of a patient’s asthma and the extent of previous symptoms and exacerbations.

Allergen control interventions may be expensive or difficult for patients to purchase or use. Clinicians do not want patients—especially those with limited financial resources—to purchase interventions that are not helpful. Further research on the effectiveness of common allergen-control strategies, and the many patient- and household-level characteristics that may influence patient outcomes, is necessary.

## Limitations of the Systematic Review Process

The scope of this review may have introduced two important limitations. First, because of the breadth of interventions we evaluated, we restricted our inclusion criteria to studies that directly evaluated an intervention. We therefore excluded all studies that presented either: (1) observational data demonstrating an association between the presence or absence of a potential allergen source (such as a pet or carpeting) and clinical outcomes or (2) nonclinical studies that examined the level of allergens on a surface. These criteria contributed to the limited evidence base for many of the interventions examined. Second, although our review encompassed a broad range of interventions, we did not assess some potentially relevant strategies that were outside the scope of this review, such as the growing role of community health workers in the implementation of asthma control strategies. We also did not examine the impact of interventions aimed at reducing irritants, such as second-hand smoke or dust, which may influence asthma outcomes.

## Limitations of the Evidence Base

The overall evidence base for interventions to reduce exposure to indoor allergens is characterized by a lack of conclusive, consistent, high- or moderate-strength evidence that either favors these strategies or demonstrates that they have no effect. We found inconclusive evidence for many comparisons and outcomes, and low-strength evidence of no effect for many others. In all of these cases, we must note the critical distinction between a lack of evidence and evidence of no effect. Throughout this review, we found that the evidence base lacks sufficient high-quality studies to inform useful conclusions for the interventions evaluated. This does not indicate that the interventions are ineffective, but rather highlights the need for additional research.

This evidence is limited in several other ways. Study size was small for many of the single- intervention studies, Heterogeneity of populations, interventions, allergens targeted, and outcomes were substantial, and we therefore did not conduct any meta-analyses of study outcomes. Results were also frequently reported in unusable ways, such as graphically without associated text or tables, or narratively without inclusion of quantitative estimates. A more systemic challenge is the lower prevalence of exacerbations and health care utilization among patients with more mild asthma. In some studies, the number of events was too small to support meaningful analysis.

Further, the risk of bias for individual studies was often difficult to assess because of incomplete reporting of important study characteristics such as randomization technique or blinding. A related consideration is the potential conflict of interest of studies funded by a manufacturer of an intervention (e.g., acaricides, air purifiers, mattress covers.) We identified only 8 out of 57 RCTs for which the funding source had a direct financial interest in the study outcomes; however, many studies did not report a funding source and/or may have received nonfinancial support through provision of study materials.

Another important limitation is the high attrition rate observed in many studies. This may be attributable partly to participants moving from one home to another or encountering instability in family life that may disrupt continuity. These challenges highlight some of the difficulties inherent in sustaining an allergen reduction strategy, in the context of both a controlled study and in real-world implementation.

Finally, researchers have been examining allergen reduction strategies for several decades. This long-term history presents its own challenge, because some of the studies we reviewed include earlier versions of interventions that have likely evolved since they were studied initially.

## Evidence Gaps

Several evidence gaps could benefit from future research. First, there is insufficient information about several types of interventions, used alone or as part of multicomponent strategies. A substantial need exists for high-quality RCTs examining the effect of HEPA vacuums, pest control, carpet removal, pet removal, and mold removal. Research is also needed to evaluate multicomponent interventions more efficiently by standardizing sets of strategies that could be tested as bundles. Head-to-head studies of interventions are also missing from the current evidence base that consists almost entirely of comparisons with placebos or standard practices. Similarly, future research could attempt to directly compare single interventions with bundled interventions.

Additionally, the evidence base could be evaluated with greater precision if outcomes reporting were improved and standardized. Important, standardized measures of asthma control, exacerbations, healthcare utilization, and quality of life were often unreported in the included studies. Moreover, many of the studies we evaluated provided data that cannot be incorporated in a comparative analysis because of incomplete reporting or reliance on graphical representations of data that lack specificity. We also need further research on the interaction between the effect size of commonly reported measures and meaningful clinical improvement. Thresholds have been developed for some measures of important asthma outcomes such as asthma control, quality of life, lung function, and medication use (see Appendix E). However, there are no agreed upon standards for the outcomes that were most frequently reported as improved in the studies we reviewed, including measures of exacerbations, absenteeism, peak flow, asthma symptoms, and allergen reduction. Establishment of thresholds for identifying clinically significant change in a wide range of outcomes is needed.

Study methodology could also be reported more consistently and comprehensively. More than half the studies we included did not report important information about their methodology, introducing the possibility of risk of bias that cannot be adequately considered.

We also found it difficult to assess the consistency of the evidence for several interventions and for many critical outcomes, because we identified only one relevant study. The addition of new studies to the evidence base and more robust outcome reporting could improve the consistency, precision, and overall strength of our conclusions.

There are also evidence gaps related to misalignment between the published studies and the population of interest. Future research can also aim to explicitly adopt the National Asthma Education and Prevention Program framework for classifying patient populations by age categories. A consistent approach to identifying “children” and “adults” will enable more standardized and robust analyses of study data.

Setting is also important. All of the studies we evaluated were conducted in patients’ homes. No studies were identified that implemented interventions in other settings where patients are routinely exposed to allergens, including workplaces, schools, and daycare.

We also highlight the need for studies that recognize the complex set of challenges that face low-income and minority groups who have the highest morbidity from asthma. Most of the studies included in this review do not describe the socioeconomic context of their patient population, and only a few seem likely to have included a substantial number of patients living in poverty and/or inner city settings despite the likelihood that these patients are at higher risk of allergen exposure and significant morbidity.

Similarly, it is important to improve our understanding of how allergen exposure interventions might directly influence health and whether they serve as markers for other influences that are not measured in these studies. For example, homes with pest infestation may be found more often in low-income neighborhoods where patients lack access to regular medical care, supermarkets with healthy foods, or social services, all of which may affect health in various ways that are not detected in the studies. More than half of the multicomponent intervention studies include a community health worker or social worker who provides education about the interventions but also link patients to a wide variety of other services. Further research on the optimal design of these community-based approaches and their impact would be useful.

We also need longitudinal studies that enable evaluation of how modifications to the home environment might have additive effects over time, or conversely, wane in effectiveness. Most of the studies we reviewed followed patients for 6 months to 1 year. Longer-term studies could help clarify the impact of these strategies and provide insight on their sustainability over time. Similarly, research is needed into how environmental interventions in childhood affect adult health. It could be important to know whether implementation of interventions at a young age can yield greater benefits as children grow.

## Conclusions

The evidence base addressing allergen-reduction interventions for patients with asthma spans 40 years and 4 continents and has included more than 7,000 patients. However, few conclusions can be reached about the effectiveness of interventions designed to reduce allergens in the home. Multicomponent interventions that include HEPA vacuums or pest control may be effective for reducing exacerbations and improving quality of life, although results were inconclusive for validated measures of asthma control. For many critical outcomes across the interventions, evidence was insufficient due to too few studies. Moreover, results that were conclusive tended to suggest lack of clinical effect. The evidence base as a whole is insufficient to support meaningful conclusions about the effectiveness of many widely used products and strategies for improving patient outcomes by reducing environmental allergen exposure. Further research on many critical questions is needed. Future research should address these evidence gaps with comparative studies that enroll enough patients to detect clinically meaningful improvements in relevant, validated asthma outcomes.