# Appendix E Minimally Important Differences

It is important to evaluate whether a measured change in an asthma outcome is clinically meaningful as well as statistically significant. Thresholds for determining clinically significant improvement have been established for some measures of asthma control, asthma-related quality of life, pulmonary physiology, and healthcare utilization, and are presented in Table E-1. The data in this table are reproduced with permission from the AHRQ EPC report, “Systematic Review of Intermittent Inhaled Corticosteroids and of Long-acting Muscarinic Antagonists for Asthma”, by the University of Connecticut Evidence-based Practice Center.

Table E-1 Thresholds for clinical significance

Instrument/Outcome | Range (points) | Final score | Threshold
ACT | 5 to 25 | Well-controlled: ≥20 Not well-controlled: ≤19 | ≥12 y: Δ 3 points^1^
ACQ5, ACQ6 | 0 to 6 | Uncontrolled: ≥1.5 Well-controlled: <0.75 | ≥18 y: Δ 0.5 points^2^
ACQ7 | 0 to 6 | Uncontrolled: ≥1.5 Well-controlled: <0.75 | ≥6 y: Δ 0.5 points^2,3^
AQLQ, AQLQ(S), AQLQ-mini | 1 to 7 | Severe impairment = 1 No impairment= 7 | ≥18 y: Δ 0.5 points^4–6^
AQLQ12+ | 1 to 7 | Severe impairment = 1 No impairment= 7 | ≥12 y: Δ 0.5 points^7,8^
PAQLQ, PACQLQ | 1 to 7 | Severe impairment = 1 No impairment= 7 | 7–17 y: Δ 0.5 points^9,10^
FEV1 | Continuous measure, L | NA | ≥18 y: −0.2 L^11^
Rescue medication use | Continuous measure, puffs per unit of time | NA | ≥18 y: −0.81 puffs/day^11^

## Reference List for Appendix E

1 Schatz M, Kosinski M, Yarlas AS, . The minimally important difference of the Asthma Control Test. J Allergy Clin Immunol. 2009 Oct;124(4):719–23.e1. Also available: http://dx.doi.org/10.1016/j.jaci.2009.06.053. PMID: 19767070.19767070
2 Juniper EF, Svensson K, Mörk AC, . Measurement properties and interpretation of three shortened versions of the asthma control questionnaire. Respir Med. 2005 May;99(5):553–8. Also available: http://dx.doi.org/10.1016/j.rmed.2004.10.008. PMID: 15823451.15823451
3 Juniper EF, Gruffydd-Jones K, Ward S, . Asthma Control Questionnaire in children: validation, measurement properties, interpretation. Eur Respir J. 2010 Dec;36(6):1410–6. Also available: http://dx.doi.org/10.1183/09031936.00117509. PMID: 20530041.20530041
4 Juniper EF, Buist AS, Cox FM, . Validation of a standardized version of the Asthma Quality of Life Questionnaire. Chest. 1999 May;115(5):1265–70. PMID: 10334138.10334138
5 Juniper EF, Guyatt GH, Cox FM, . Development and validation of the Mini Asthma Quality of Life Questionnaire. Eur Respir J. 1999 Jul;14(1):32–8. PMID: 10489826.10489826
6 Juniper EF, Guyatt GH, Willan A, . Determining a minimal important change in a disease-specific Quality of Life Questionnaire. J Clin Epidemiol. 1994 Jan;47(1):81–7. PMID: 8283197.8283197
7 Juniper EF, Svensson K, Mörk AC, . Modification of the asthma quality of life questionnaire (standardised) for patients 12 years and older. Health Qual Life Outcomes. 2005 Sep 16;3:58. Also available: http://dx.doi.org/10.1186/1477-7525-3-58. PMID: 16168050.16168050
8 Wyrwich KW, Ireland AM, Navaratnam P, . Validation of the AQLQ12+ among adolescents and adults with persistent asthma. Qual Life Res. 2011 Aug;20(6):903–12. Also available: http://dx.doi.org/10.1007/s11136-010-9821-3. PMID: 21184185.21184185
9 Juniper EF, Guyatt GH, Feeny DH, . Measuring quality of life in children with asthma. Qual Life Res. 1996 Feb;5(1):35–46. PMID: 8901365.8901365
10 Juniper EF, Guyatt GH, Feeny DH, . Measuring quality of life in the parents of children with asthma. Qual Life Res. 1996 Feb;5(1):27–34. PMID: 8901364.8901364
11 Santanello NC, Zhang J, Seidenberg B, . What are minimal important changes for asthma measures in a clinical trial? Eur Respir J. 1999 Jul;14(1):23–7. PMID: 10489824.10489824