# Appendix D Qualitative Comparative Analysis

The analytic steps of the qualitative comparative analysis (QCA) are described below:

1. [underlined: Specifying the configural questions]. For this review, we asked, “What allergen reduction intervention or combination of intervention components is present in studies demonstrating improved asthma outcomes?”
2. [underlined: Identifying cases for use in analysis]. Randomized controlled trials were included if they: a) examined one of the six types of interventions that were previously evaluated as a single intervention, or a strategy within multicomponent intervention studies (i.e., acaricide, air purification, carpet removal, HEPA vacuum, mattress cover, and pest control); and b) reported data on a primary outcome (i.e., asthma control, exacerbations, healthcare utilization, quality of life, and pulmonary physiology.)
3. [underlined: Specifying and calibrating condition sets]. Condition and outcome sets are calibrated by establishing thresholds and decision rules for membership in a condition. In a crisp set, a value of 1 indicates that a case is fully in the condition set; a value of 0 indicates that a case is fully out of a condition set. We employed a crisp set, where each intervention either was, or was not, used in each study. A value of 1 indicated that an intervention was used in the active arm but not the control arm of a study, while a value of 0 indicated that a given intervention was not examined in that study.
  We also considered other sets of conditions for analysis, in addition to specific intervention strategies. We were especially interested in whether outcomes varied by any of the following characteristics: (a) study population age; (b) use of a single strategy compared with multicomponent interventions; and (c) use of strategies that targeted only one type of allergen compared with interventions that addressed multiple allergens. Therefore, we classified studies according to whether the population was exclusively pediatric (under the age of 12, per our methods for this review), and whether an intervention was implemented in isolation or as part of a multicomponent approach. We also coded studies based on whether their included intervention(s) would be expected to reduce exposure to a single type of allergen, such as acaricide for house dust mites, or multiple allergens, as would apply to air purifiers.
  Although we had 49 studies for analysis, only 22 reported positive findings for a primary outcome. We therefore needed to limit the number of conditions we could test. Because QCA examines all possible combinations of conditions, adding conditions to a model increases the number of possible combinations exponentially (by 2 to the kth power, where k is the number of conditions. Thus, three conditions produce eight combinations, four conditions produce 16 combinations, and so on). After preliminary analysis, we discovered that inclusion of population and study characteristics as described above did not result in useful findings, and diluted the QCA model. We therefore removed these conditions from the model, and completed the analysis by examining only the six types of interventions discussed above.
4. [underlined: Specifying the outcome set]. We assigned a value of 1 if a study reported significant improvement in at least one measure of one primary outcome (i.e., asthma control, exacerbations, healthcare utilization, pulmonary physiology, or quality of life,) even if other measures or outcomes within the study found no effect. We assigned a value of 0 to cases that did not demonstrate any statistically significant improvement in any measure of any primary outcome. Table D-1 presents the intervention and outcome inputs for each study.
5. [underlined: Constructing and analyzing the truth table]. The truth table is the main analytic device in QCA. Analysis of the truth table helps to determine which interventions or combination of conditions are consistently present in studies that report improved outcomes. We used R Set Methods and QCA packages to identify “solutions,” which are combinations of conditions that are necessary or sufficient to produce a given outcome. This analysis also included examination of two parameters of fit: consistency and coverage. Consistency assesses the proportion of studies with a given intervention that achieved the outcome, within an individual solution or across solutions. High consistency indicates that all or most studies that included a given intervention achieved the desired outcome. Coverage examines variation in how well a solution accounts for outcomes across all studies. High coverage indicates that a given intervention (or combination of interventions) is present in all or most of the studies that reported a desired outcome.
  The results of a QCA analysis are statements of necessity and sufficiency. We assessed each individual condition for necessity and sufficiency, examined the necessary and sufficient combinations of conditions that resulted in significant improvements, and calculated consistency and coverage. We explored three types of solutions, which differ based on the assumptions that the model makes about the “remainders,” which are the combinations of conditions that theoretically could exist but were not present in any of the included studies. These solutions are categorized as conservative, intermediate, and parsimonious. We implemented a 0.80 consistency level for including combinations in the final minimization model. As is typical in QCA practice, we report the intermediate solution in the Results of the report. The conservative and parsimonious solutions, which are a subset and a superset (respectively) of the intermediate solution, are shown in Figure D-1 and Figure D-2.

Table D-1 QCA input table

Study | Acaricide | Air Purification | Carpet Removal | HEPA Vacuum | Mattress Covers | Pest Control | Primary Outcome
Matsui et al. 2017^1^ | 0 | 0 | 0 | 0 | 0 | 1 | 0
Rabito et al. 2017^2^ | 0 | 0 | 0 | 0 | 0 | 1 | 1
DiMango et al. 2016^3^ | 0 | 1 | 0 | 1 | 1 | 0 | 0
El-Ghitany et al. 2012^4^ | 1 | 0 | 1 | 0 | 1 | 0 | 1
Bryant-Stephens et al. 2009^5^ | 0 | 0 | 1 | 0 | 1 | 1 | 0
Krieger et al. 2009^6^ | 0 | 0 | 0 | 1 | 0 | 0 | 1
Bryant-Stephens et al. 2008^7^ | 0 | 0 | 1 | 0 | 1 | 1 | 0
Parker et al. 2008^8^ | 0 | 0 | 0 | 1 | 1 | 1 | 1
Eggleston et al. 2005^9^ | 0 | 1 | 0 | 0 | 1 | 1 | 0
Krieger et al. 2005^10^ | 0 | 0 | 0 | 1 | 0 | 1 | 1
Morgan et al. 2004^11^ | 0 | 1 | 0 | 1 | 1 | 1 | 1
Carter et al. 2001^12^ | 0 | 0 | 0 | 0 | 1 | 1 | 1
Warner et al. 2000^13^ | 0 | 0 | 0 | 1 | 0 | 0 | 0
Cloosterman et al. 1999^14^ | 1 | 0 | 0 | 0 | 1 | 0 | 0
Evans et al. 1999^15^ | 0 | 0 | 0 | 0 | 1 | 1 | 0
Shapiro et al. 1999^16^ | 1 | 0 | 0 | 0 | 1 | 0 | 1
Hayden et al. 1997^17^ | 1 | 0 | 1 | 0 | 1 | 0 | 1
Carswell et al. 1996^18^ | 1 | 0 | 0 | 0 | 1 | 0 | 1
Marks et al. 1994^19^ | 1 | 0 | 0 | 0 | 1 | 0 | 0
Korsgaard et al. 1983^20^ | 0 | 0 | 1 | 0 | 0 | 0 | 1
Bahir et al. 1997^21^ | 1 | 0 | 0 | 0 | 0 | 0 | 0
Chang et al. 1996^22^ | 1 | 0 | 0 | 0 | 0 | 0 | 0
Sette et al. 1994^23^ | 1 | 0 | 0 | 0 | 0 | 0 | 1
Dietemann et al. 1993^24^ | 1 | 0 | 0 | 0 | 0 | 0 | 0
Reiser et al. 1990^25^ | 1 | 0 | 0 | 0 | 0 | 0 | 0
Pedroletti et al. 2009^26^ | 0 | 1 | 0 | 0 | 0 | 0 | 1
Wright et al. 2009^27^ | 0 | 1 | 0 | 0 | 0 | 0 | 1
Sulser et al. 2008^28^ | 0 | 1 | 0 | 0 | 0 | 0 | 0
Francis et al. 2003^29^ | 0 | 1 | 0 | 0 | 0 | 0 | 1
Van der Heide et al. 1999^30^ | 0 | 1 | 0 | 0 | 0 | 0 | 1
Van der Heide et al. 1997^31^ | 0 | 1 | 0 | 0 | 0 | 0 | 0
Warner et al. 1993^32^ | 0 | 1 | 0 | 0 | 0 | 0 | 0
Mitchell et al. 1980^33^ | 0 | 1 | 0 | 0 | 0 | 0 | 0
Zwemer et al. 1973^34^ | 0 | 1 | 0 | 0 | 0 | 0 | 0
Popplewell et al. 2000^35^ | 0 | 0 | 0 | 1 | 0 | 0 | 1
Murray et al. 2017^36^ | 0 | 0 | 0 | 0 | 1 | 0 | 1
Tsurikisawa et al. 2016^37^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Tsurikisawa et al. 2013^38^ | 0 | 0 | 0 | 0 | 1 | 0 | 1
de Vries et al. 2007^39^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Dharmage et al. 2006^40^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
van den Bemt et al. 2004^41^ | 0 | 0 | 0 | 0 | 1 | 0 | 1
Halken et al. 2003^42^ | 0 | 0 | 0 | 0 | 1 | 0 | 1
Luczynska et al. 2003^43^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Woodcock et al. 2003^44^ | 0 | 0 | 0 | 0 | 1 | 0 | 1
Rijssenbeek-Nouwens et al. 2002^45^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Sheikh et al. 2002^46^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Frederick et al. 1997^47^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Burr et al. 1980^48^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Burr et al. 1976^49^ | 0 | 0 | 0 | 0 | 1 | 0 | 0
Total (N=49) | 11 | 12 | 5 | 7 | 28 | 10 | 22

HEPA=high-efficiency particulate air-filtration

Figure D-1 Conservative solution

Figure D-1 provides the conservative solution set derived from the QCA analysis. There were four solutions in this analysis. The first solution includes HEPA vacuums and pest control, without acaricide or air purification or carpet removal. The second solution includes HEPA vacuums and pest control and mattress covers, without acaricide or carpet removal. Solution 3 includes carpet removal without acaricide or air purification or HEPA vacuums or mattress covers or pest control. The fourth solution includes acaricides and carpet removal and mattress covers, without air purification or HEPA vacuums or pest control.

Figure D-2 Parsimonious solution

Figure D-2 represents the parsimonious solution set of the QCA analysis. This solution set is identical to the intermediate solution depicted in Figure 5.

## Reference List for Appendix D

1 Matsui EC, Perzanowski M, Peng RD, . Effect of an integrated pest management intervention on asthma symptoms among mouse-sensitized children and adolescents with asthma: a randomized clinical trial. JAMA. 2017 Mar 14;317(10):1027–36. Also available: http://dx.doi.org/10.1001/jama.2016.21048. PMID: 28264080.28264080
2 Rabito FA, Carlson JC, He H, . A single intervention for cockroach control reduces cockroach exposure and asthma morbidity in children. J Allergy Clin Immunol. 2017 Jan 10;S0091-6749(16):31349–5. [Epub ahead of print]. Also available: http://dx.doi.org/10.1016/j.jaci.2016.10.019. PMID: 28108117.28108117
3 DiMango E, Serebrisky D, Narula S, . Individualized household allergen intervention lowers allergen level but not asthma medication use: a randomized controlled trial. J Allergy Clin Immunol Pract. 2016 Jul–Aug;4(4):671–679.e4. Also available: http://dx.doi.org/10.1016/j.jaip.2016.01.016. PMID: 27025297.27025297
4 El-Ghitany EM, El-Salam MM. Environmental intervention for house dust mite control in childhood bronchial asthma. Environ Health Prevent Med. 2012 Sep;17(5):377–84. Also available: http://dx.doi.org/10.1007/s12199-011-0263-5. PMID: 22302565.22302565
5 Bryant-Stephens T, Kurian C, Guo R, . Impact of a household environmental intervention delivered by lay health workers on asthma symptom control in urban, disadvantaged children with asthma. Am J Public Health. 2009 Nov;(99 Suppl 3):S657–65. PMID: 19890172.19890172
6 Krieger J, Takaro TK, Song L, . A randomized controlled trial of asthma self-management support comparing clinic-based nurses and in-home community health workers: the Seattle-King County Healthy Homes II Project. Arch Pediatr Adolesc Med. 2009 Feb;163(2):141–9. Also available: http://dx.doi.org/10.1001/archpediatrics.2008.532. PMID: 19188646.19188646
7 Bryant-Stephens T, Li Y. Outcomes of a home-based environmental remediation for urban children with asthma. J Natl Med Assoc. 2008 Mar;100(3):306–16. PMID: 18390024.18390024
8 Parker EA, Israel BA, Robins TG, . Evaluation of community action against asthma: a community health worker intervention to improve children’s asthma-related health by reducing household environmental triggers for asthma. Health Educ Behav. 2008 Jun;35(3):376–95. Also available: http://dx.doi.org/10.1177/1090198106290622. PMID: 17761540.17761540
9 Eggleston PA, Butz A, Rand C, . Home environmental intervention in inner-city asthma: a randomized controlled clinical trial. Ann Allergy Asthma Immunol. 2005 Dec;95(6):518–24. PMID: 16400889.16400889
10 Krieger JW, Takaro TK, Song L, . The Seattle-King County Healthy Homes Project: a randomized, controlled trial of a community health worker intervention to decrease exposure to indoor asthma triggers. Am J Public Health. 2005 Apr;95(4):652–9. Also available: http://dx.doi.org/10.2105/AJPH.2004.042994. PMID: 15798126.15798126
11 Morgan WJ, Crain EF, Gruchalla RS, . Results of a home-based environmental intervention among urban children with asthma. N Engl J Med. 2004 Sep 9;351(11):1068–80. Also available: http://dx.doi.org/10.1056/NEJMoa032097. PMID: 15356304.15356304
12 Carter MC, Perzanowski MS, Raymond A, . Home intervention in the treatment of asthma among inner-city children. J Allergy Clin Immunol. 2001;108(5):732–7. Also available: http://dx.doi.org/10.1067/mai.2001.119155. PMID: 11692097.11692097
13 Warner JA, Frederick JM, Bryant TN, . Mechanical ventilation and high-efficiency vacuum cleaning: a combined strategy of mite and mite allergen reduction in the control of mite-sensitive asthma. J Allergy Clin Immunol. 2000;105(1):75–82. PMID: 10629456.10629456
14 Cloosterman SG, Schermer TR, Bijl-Hofland ID, . Effects of house dust mite avoidance measures on Der p 1 concentrations and clinical condition of mild adult house dust mite-allergic asthmatic patients, using no inhaled steroids. Clin Exp Allergy. 1999;29(10):1336–46. Also available: http://dx.doi.org/10.1046/j.1365-2222.1999.00627.x. PMID: 10520054.10520054
15 Evans R III, Gergen PJ, Mitchell H, . A randomized clinical trial to reduce asthma morbidity among inner-city children: results of the National Cooperative Inner-City Asthma Study. J Pediatr. 1999 Sep;135(3):332–8. PMID: 10484799.10484799
16 Shapiro GG, Wighton TG, Chinn T, . House dust mite avoidance for children with asthma in homes of low- income families. J Allergy Clin Immunol. 1999;103(6):1069–74. Also available: http://dx.doi.org/10.1016/S0091-6749(99)70181-8. PMID: 10359888.10359888
17 Hayden ML, Perzanowski M, Matheson L, . Dust mite allergen avoidance in the treatment of hospitalized children with asthma. Ann Allergy Asthma Immunol. 1997;79(5):437–42. PMID: 9396978.9396978
18 Carswell F, Birmingham K, Oliver J, . The respiratory effects of reduction of mite allergen in the bedrooms of asthmatic children - a double-blind controlled trial. Clin Exp Allergy. 1996;26(4):386–96. Also available: http://dx.doi.org/10.1111/j.1365-2222.1996.tb00554.x. PMID: 8732235.8732235
19 Marks GB, Tovey ER, Green W, . House dust mite allergen avoidance: a randomized controlled trial of surface chemical treatment and encasement of bedding. Clin Exp Allergy. 1994;24(11):1078–83. Also available: http://dx.doi.org/10.1111/j.1365-2222.1994.tb02746.x. PMID: 7677828.7677828
20 Korsgaard J. Preventive measures in mite asthma. A controlled trial. Allergy. 1983 Feb;38(2):93–102. PMID: 6342456.6342456
21 Bahir A, Goldberg A, Mekori YA, . Continuous avoidance measures with or without acaricide in dust mite-allergic asthmatic children. Ann Allergy Asthma Immunol. 1997 May;78(5):506–12. PMID: 9164365.9164365
22 Chang JH, Becker A, Ferguson A, . Effect of application of benzyl benzoate on house dust mite allergen levels. Ann Allergy Asthma Immunol. 1996 Sep;77(3):187–90. PMID: 8814042.8814042
23 Sette L, Comis A, Marcucci F, . Benzyl-benzoate foam: effects on mite allergens in mattress, serum and nasal secretory IgE to dermatophagoides pteronyssinus, and bronchial hyperreactivity in children with allergic asthma. Pediatr Pulmonol. 1994 Oct;18(4):218–27. PMID: 7838620.7838620
24 Dietemann A, Bessot JC, Hoyet C, . A double-blind, placebo controlled trial of solidified benzyl benzoate applied in dwellings of asthmatic patients sensitive to mites: clinical efficacy and effect on mite allergens. J Allergy Clin Immunol. 1993;91(3):738–46. PMID: 8454796.8454796
25 Reiser J, Ingram D, Mitchell EB, . House dust mite allergen levels and an anti-mite mattress spray (natamycin) in the treatment of childhood asthma. Clin Exp Allergy. 1990;20(5):561–7. PMID: 2253088.2253088
26 Pedroletti C, Millinger E, Dahlén B, . Clinical effects of purified air administered to the breathing zone in allergic asthma: a double-blind randomized cross-over trial. Respir Med. 2009 Sep;103(9):1313–9. Also available: http://dx.doi.org/10.1016/j.rmed.2009.03.020. PMID: 19443189.19443189
27 Wright GR, Howieson S, McSharry C, . Effect of improved home ventilation on asthma control and house dust mite allergen levels. Allergy. 2009 Nov;64(11):1671–80. Also available: http://dx.doi.org/10.1111/j.1398-9995.2009.02098.x. PMID: 19650848.19650848
28 Sulser C, Schulz G, Wagner P, . Can the use of HEPA cleaners in homes of asthmatic children and adolescents sensitized to cat and dog allergens decrease bronchial hyperresponsiveness and allergen contents in solid dust? Int Arch Allergy Immunol. 2008 Dec;148(1):23–30. Also available: http://dx.doi.org/10.1159/000151502. PMID: 18716400.18716400
29 Francis H, Fletcher G, Anthony C, . Clinical effects of air filters in homes of asthmatic adults sensitized and exposed to pet allergens. Clin Exp Allergy. 2003;33(1):101–5. Also available: http://dx.doi.org/10.1046/j.1365-2222.2003.01570.x. PMID: 12534557.12534557
30 van der Heide S, van Aalderen WM, Kauffman HF, . Clinical effects of air cleaners in homes of asthmatic children sensitized to pet allergens. J Allergy Clin Immunol. 1999;104(2):447–51. Also available: http://dx.doi.org/10.1016/S0091-6749(99)70391-X. PMID: 10452769.10452769
31 van der Heide S, Kauffman HF, Dubois AE, . Allergen reduction measures in houses of allergic asthmatic patients: effects of air-cleaners and allergen-impermeable mattress covers. Eur Respir J. 1997 Jun;10(6):1217–23. Also available: http://dx.doi.org/10.1183/09031936.97.10061217. PMID: 9192919.9192919
32 Warner JA, Marchant JL, Warner JO. Double blind trial of ionisers in children with asthma sensitive to the house dust mite. Thorax. 1993;48(4):330–3. PMID: 8511730.8511730
33 Mitchell EA, Elliott RB. Controlled trial of an electrostatic precipitator in childhood asthma. Lancet. 1980 Sep 13;2(8194):559–61. PMID: 6106739.6106739
34 Zwemer RJ, Karibo J. Use of laminar control device as adjunct to standard environmental control measures in symptomatic asthmatic children. Ann Allergy. 1973 Jun;31(6):284–90. PMID: 4710748.4710748
35 Popplewell EJ, Innes VA, Lloyd-Hughes S, . The effect of high-efficiency and standard vacuum-cleaners on mite, cat and dog allergen levels and clinical progress. Pediatr Allergy Immunol. 2000;11(3):142–8. Also available: http://dx.doi.org/10.1034/j.1399-3038.2000.00058.x. PMID: 10981523.10981523
36 Murray CS, Foden P, Sumner H, . Preventing severe asthma exacerbations in children: a randomised trial of mite impermeable bedcovers. Am J Respir Crit Care Med. 2017 Mar 10. [Epub ahead of print]. Also available: http://dx.doi.org/10.1164/rccm.201609-1966OC. PMID: 28282501.28282501
37 Tsurikisawa N, Saito A, Oshikata C, . Effective allergen avoidance for reducing exposure to house dust mite allergens and improving disease management in adult atopic asthmatics. J Asthma. 2016 Oct;53(8):843–53. Epub 2016 Apr 6. Also available: http://dx.doi.org/10.3109/02770903.2016.1155218. PMID: 27049597.27049597
38 Tsurikisawa N, Saito A, Oshikata C, . Encasing bedding in covers made of microfine fibers reduces exposure to house mite allergens and improves disease management in adult atopic asthmatics. Allergy Asthma Clin Immunol. 2013;9(1):44. Also available: http://dx.doi.org/10.1186/1710-1492-9-44. PMID: 24499343.24499343
39 de Vries MP, van den Bemt L, Aretz K, . House dust mite allergen avoidance and self-management in allergic patients with asthma: randomised controlled trial. Br J Gen Pract. 2007 Mar;57(536):184–90. PMID: 17359604.17359604
40 Dharmage S, Walters EH, Thien F, . Encasement of bedding does not improve asthma in atopic adult asthmatics. Int Arch Allergy Immunol. 2006 Jan;139(2):132–8. Also available: http://dx.doi.org/10.1159/000090388. PMID: 16374022.16374022
41 van den Bemt L, van Knapen L, de Vries MP, . Clinical effectiveness of a mite allergen-impermeable bed-covering system in asthmatic mite-sensitive patients. J Allergy Clin Immunol. 2004 Oct;114(4):858–62. Also available: http://dx.doi.org/10.1016/j.jaci.2004.05.069. PMID: 15480327.15480327
42 Halken S, Host A, Niklassen U, . Effect of mattress and pillow encasings on children with asthma and house dust mite allergy. J Allergy Clin Immunol. 2003 Jan 1;111(1):169–76. Also available: http://dx.doi.org/10.1067/mai.2003.5. PMID: 12532114.12532114
43 Luczynska C, Tredwell E, Smeeton N, . A randomized controlled trial of mite allergen-impermeable bed covers in adult mite-sensitized asthmatics. Clin Exp Allergy. 2003 Dec;33(12):1648–53. Also available: http://dx.doi.org/10.1111/j.1365-2222.2003.01729.x. PMID: 14656350.14656350
44 Woodcock A, Forster L, Matthews E, . Control of exposure to mite allergen and allergen-impermeable bed covers for adults with asthma. N Engl J Med. 2003 Jul 17;349(3):225–36. Also available: http://dx.doi.org/10.1056/NEJMoa023175. PMID: 12867606.12867606
45 Rijssenbeek-Nouwens LH, Oosting AJ, de Bruin-Weller MS, . Clinical evaluation of the effect of anti-allergic mattress covers in patients with moderate to severe asthma and house dust mite allergy: a randomised double blind placebo controlled study. Thorax. 2002 Sep;57(9):784–90. Also available: http://dx.doi.org/10.1136/thorax.57.9.784. PMID: 12200523.12200523
46 Sheikh A, Hurwitz B, Sibbald B, . House dust mite barrier bedding for childhood asthma: randomised placebocontrolled trial in primary care [ISRCTN63308372]. BMC Fam Pract. 2002 Jun 18;1–6. PMID: 12079502.11835692
47 Frederick JM, Warner JO, Jessop WJ, . Effect of a bed covering system in children with asthma and house dust mite hypersensitivity. Eur Respir J. 1997 Feb;10(2):361–6. Also available: http://dx.doi.org/10.1183/09031936.97.10020361. PMID: 9042633.9042633
48 Burr ML, Neale E, Dean BV, . Effect of a change to mite-free bedding on children with mite-sensitive asthma: a controlled trial. Thorax. 1980 Jul;35(7):513–4. PMID: 7001668.7001668
49 Burr ML, St Leger AS, Neale E. Anti-mite measurements in mite-sensitive adult asthma. A controlled trial. Lancet. 1976 Feb 14;1(7955):333–5. PMID: 54740.54740