# Appendix C Evidence Tables

## Key Question 1 Allergen Reduction for Management of Asthma

### Evidence Tables for Acaricide (Dust Mite Pesticide) Studies

Table C-1 Study characteristics of acaricide (dust mite pesticide) studies

Table C-2 Outcomes of acaricide (dust mite pesticide) studies

Table C-3 Risk of bias of acaricide (dust mite pesticide) randomized controlled trials

Table C-4 Risk of bias of acaricide (dust mite pesticide) non-randomized controlled trial

### Evidence Tables for Air Purification Studies

Table C-5 Study characteristics of air purification studies

Table C-6 Outcomes of air purification studies

Table C-7 Risk of bias of air purification randomized controlled trials

### Evidence Tables for High-Efficiency Particulate Air-Filtration (HEPA) Vacuum Studies

Table C-8 Study characteristics of HEPA vacuum study

Table C-9 Outcomes of HEPA vacuum study

Table C-10 Risk of bias of HEPA vacuum randomized controlled trial

### Evidence Tables for Mattress Cover Studies

Table C-11 Study characteristics of mattress cover studies

Table C-12 Outcomes of mattress cover studies

Table C-13 Risk of bias of mattress cover randomized controlled trials

### Evidence Tables for Pest Control Studies

Table C-14 Study characteristics of pest control study

Table C-15 Outcomes of pest control study

Table C-16 Risk of bias of pest control randomized controlled trial

Table C-17 Risk of bias of pest control non-randomized study

### Evidence Tables for Pet Removal Studies

Table C-18 Study characteristics of pet removal study

Table C-19 Outcomes of pet removal study

Table C-20 Risk of bias of pet removal non-randomized study

### Evidence Tables for Other/Miscellaneous Intervention Studies

Table C-21 Study characteristics of other/miscellaneous intervention study

Table C-22 Outcomes of other/miscellaneous intervention study

Table C-23 Risk of bias of other/miscellaneous randomized controlled trial

### Evidence Tables for Multicomponent Intervention Studies

Table C-24 Study characteristics of multicomponent intervention studies

Table C-25 Outcomes of multicomponent intervention studies

Table-C-26 Risk of bias of multicomponent intervention randomized controlled trials

Table C-27 Risk of bias of multicomponent intervention non-randomized controlled trials

## Reference List for Appendix C

1 Bahir A, Goldberg A, Mekori YA, . Continuous avoidance measures with or without acaricide in dust mite-allergic asthmatic children. Ann Allergy Asthma Immunol. 1997 May;78(5):506–12. PMID: 9164365.9164365
2 van der Heide S, Kauffman HF, Dubois AE, . Allergen-avoidance measures in homes of house-dust-mite-allergic asthmatic patients: effects of acaricides and mattress encasings. Allergy. 1997;52(9):921–7. PMID: 9298177.9298177
3 Chang JH, Becker A, Ferguson A, . Effect of application of benzyl benzoate on house dust mite allergen levels. Ann Allergy Asthma Immunol. 1996 Sep;77(3):187–90. PMID: 8814042.8814042
4 Geller-Bernstein C, Pibourdin JM, Dornelas A, . Efficacy of the acaricide: acardust for the prevention of asthma and rhinitis due to dust mite allergy, in children. Allerg Immunol (Paris). 1995;27(5):147–54. PMID: 7662102.7662102
5 Sette L, Comis A, Marcucci F, . Benzyl-benzoate foam: effects on mite allergens in mattress, serum and nasal secretory IgE to dermatophagoides pteronyssinus, and bronchial hyperreactivity in children with allergic asthma. Pediatr Pulmonol. 1994 Oct;18(4):218–27. PMID: 7838620.7838620
6 Dietemann A, Bessot JC, Hoyet C, . A double-blind, placebo controlled trial of solidified benzyl benzoate applied in dwellings of asthmatic patients sensitive to mites: clinical efficacy and effect on mite allergens. J Allergy Clin Immunol. 1993;91(3):738–46. PMID: 8454796.8454796
7 Reiser J, Ingram D, Mitchell EB, . House dust mite allergen levels and an anti-mite mattress spray (natamycin) in the treatment of childhood asthma. Clin Exp Allergy. 1990;20(5):561–7. PMID: 2253088.2253088
8 Pedroletti C, Millinger E, Dahlén B, . Clinical effects of purified air administered to the breathing zone in allergic asthma: a double-blind randomized cross-over trial. Respir Med. 2009 Sep;103(9):1313–9. Also available: http://dx.doi.org/10.1016/j.rmed.2009.03.020. PMID: 19443189.19443189
9 Wright GR, Howieson S, McSharry C, . Effect of improved home ventilation on asthma control and house dust mite allergen levels. Allergy. 2009 Nov;64(11):1671–80. Also available: http://dx.doi.org/10.1111/j.1398-9995.2009.02098.x. PMID: 19650848.19650848
10 Sulser C, Schulz G, Wagner P, . Can the use of HEPA cleaners in homes of asthmatic children and adolescents sensitized to cat and dog allergens decrease bronchial hyperresponsiveness and allergen contents in solid dust? Int Arch Allergy Immunol. 2008 Dec;148(1):23–30. Also available: http://dx.doi.org/10.1159/000151502. PMID: 18716400.18716400
11 Francis H, Fletcher G, Anthony C, . Clinical effects of air filters in homes of asthmatic adults sensitized and exposed to pet allergens. Clin Exp Allergy. 2003;33(1):101–5. Also available: http://dx.doi.org/10.1046/j.1365-2222.2003.01570.x. PMID: 12534557.12534557
12 van der Heide S, van Aalderen WM, Kauffman HF, . Clinical effects of air cleaners in homes of asthmatic children sensitized to pet allergens. J Allergy Clin Immunol. 1999;104(2):447–51. Also available: http://dx.doi.org/10.1016/S0091-6749(99)70391-X. PMID: 10452769.10452769
13 van der Heide S, Kauffman HF, Dubois AE, . Allergen reduction measures in houses of allergic asthmatic patients: effects of air-cleaners and allergen-impermeable mattress covers. Eur Respir J. 1997 Jun;10(6):1217–23. Also available: http://dx.doi.org/10.1183/09031936.97.10061217. PMID: 9192919.9192919
14 Warner JA, Marchant JL, Warner JO. Double blind trial of ionisers in children with asthma sensitive to the house dust mite. Thorax. 1993;48(4):330–3. PMID: 8511730.8511730
15 Mitchell EA, Elliott RB. Controlled trial of an electrostatic precipitator in childhood asthma. Lancet. 1980 Sep 13;2(8194):559–61. PMID: 6106739.6106739
16 Zwemer RJ, Karibo J. Use of laminar control device as adjunct to standard environmental control measures in symptomatic asthmatic children. Ann Allergy. 1973 Jun;31(6):284–90. PMID: 4710748.4710748
17 Popplewell EJ, Innes VA, Lloyd-Hughes S, . The effect of high-efficiency and standard vacuum-cleaners on mite, cat and dog allergen levels and clinical progress. Pediatr Allergy Immunol. 2000;11(3):142–8. Also available: http://dx.doi.org/10.1034/j.1399-3038.2000.00058.x. PMID: 10981523.10981523
18 Murray CS, Foden P, Sumner H, . Preventing severe asthma exacerbations in children: a randomised trial of mite impermeable bedcovers. Am J Respir Crit Care Med. 2017 Mar 10. [Epub ahead of print]. Also available: http://dx.doi.org/10.1164/rccm.201609-1966OC. PMID: 28282501.28282501
19 Tsurikisawa N, Saito A, Oshikata C, . Effective allergen avoidance for reducing exposure to house dust mite allergens and improving disease management in adult atopic asthmatics. J Asthma. 2016 Oct;53(8):843–53. Epub 2016 Apr 6. Also available: http://dx.doi.org/10.3109/02770903.2016.1155218. PMID: 27049597.27049597
20 Tsurikisawa N, Saito A, Oshikata C, . Encasing bedding in covers made of microfine fibers reduces exposure to house mite allergens and improves disease management in adult atopic asthmatics. Allergy Asthma Clin Immunol. 2013;9(1):44. Also available: http://dx.doi.org/10.1186/1710-1492-9-44. PMID: 24499343.24499343
21 Glasgow NJ, Ponsonby AL, Kemp A, . Feather bedding and childhood asthma associated with house dust mite sensitisation: a randomised controlled trial. Arch Dis Child. 2011 Jun;96(6):541–7. Also available: http://dx.doi.org/10.1136/adc.2010.189696. PMID: 21451166.21451166
22 Nambu M, Shirai H, Sakaguchi M, . Effect of house dust mite-free pillow on clinical course of asthma and IgE level -- a randomized, double-blind, controlled study. Pediatr Asthma Allergy Immunol. 2008 Sep;21(3):137–44.
23 de Vries MP, van den Bemt L, Aretz K, . House dust mite allergen avoidance and self-management in allergic patients with asthma: randomised controlled trial. Br J Gen Pract. 2007 Mar;57(536):184–90. PMID: 17359604.17359604
24 van den Bemt L, de Vries MP, Cloosterman S, . Influence of house dust mite impermeable covers on health-related quality of life of adult patients with asthma: Results of a randomized clinical trial. J Asthma. 2007 Dec;44(10):843–8. Also available: http://dx.doi.org/10.1080/02770900701752318. PMID: 18097861.18097861
25 Dharmage S, Walters EH, Thien F, . Encasement of bedding does not improve asthma in atopic adult asthmatics. Int Arch Allergy Immunol. 2006 Jan;139(2):132–8. Also available: http://dx.doi.org/10.1159/000090388. PMID: 16374022.16374022
26 van den Bemt L, van Knapen L, de Vries MP, . Clinical effectiveness of a mite allergen-impermeable bed-covering system in asthmatic mite-sensitive patients. J Allergy Clin Immunol. 2004 Oct;114(4):858–62. Also available: http://dx.doi.org/10.1016/j.jaci.2004.05.069. PMID: 15480327.15480327
27 Halken S, Host A, Niklassen U, . Effect of mattress and pillow encasings on children with asthma and house dust mite allergy. J Allergy Clin Immunol. 2003 Jan 1;111(1):169–76. Also available: http://dx.doi.org/10.1067/mai.2003.5. PMID: 12532114.12532114
28 Lee IS. Effect of bedding control on amount of house dust mite allergens, asthma symptoms, and peak expiratory flow rate. Yonsei Med J. 2003 Apr 30;44(2):313–22. PMID: 12728474.12728474
29 Luczynska C, Tredwell E, Smeeton N, . A randomized controlled trial of mite allergen-impermeable bed covers in adult mite-sensitized asthmatics. Clin Exp Allergy. 2003 Dec;33(12):1648–53. Also available: http://dx.doi.org/10.1111/j.1365-2222.2003.01729.x. PMID: 14656350.14656350
30 Woodcock A, Forster L, Matthews E, . Control of exposure to mite allergen and allergen-impermeable bed covers for adults with asthma. N Engl J Med. 2003 Jul 17;349(3):225–36. Also available: http://dx.doi.org/10.1056/NEJMoa023175. PMID: 12867606.12867606
31 Rijssenbeek-Nouwens LH, Oosting AJ, de Bruin-Weller MS, . Clinical evaluation of the effect of anti-allergic mattress covers in patients with moderate to severe asthma and house dust mite allergy: a randomised double blind placebo controlled study. Thorax. 2002 Sep;57(9):784–90. Also available: http://dx.doi.org/10.1136/thorax.57.9.784. PMID: 12200523.12200523
32 Sheikh A, Hurwitz B, Sibbald B, . House dust mite barrier bedding for childhood asthma: randomised placebocontrolled trial in primary care [ISRCTN63308372]. BMC Fam Pract. 2002 Jun 18;1–6. PMID: 12079502.11835692
33 Frederick JM, Warner JO, Jessop WJ, . Effect of a bed covering system in children with asthma and house dust mite hypersensitivity. Eur Respir J. 1997 Feb;10(2):361–6. Also available: http://dx.doi.org/10.1183/09031936.97.10020361. PMID: 9042633.9042633
34 Burr ML, Neale E, Dean BV, . Effect of a change to mite-free bedding on children with mite-sensitive asthma: a controlled trial. Thorax. 1980 Jul;35(7):513–4. PMID: 7001668.7001668
35 Burr ML, St Leger AS, Neale E. Anti-mite measurements in mite-sensitive adult asthma. A controlled trial. Lancet. 1976 Feb 14;1(7955):333–5. PMID: 54740.54740
36 Rabito FA, Carlson JC, He H, . A single intervention for cockroach control reduces cockroach exposure and asthma morbidity in children. J Allergy Clin Immunol. 2017 Jan 10;S0091-6749(16):31349–5. [Epub ahead of print]. Also available: http://dx.doi.org/10.1016/j.jaci.2016.10.019. PMID: 28108117.28108117
37 Levy JI, Brugge D, Peters JL, . A community-based participatory research study of multifaceted in-home environmental interventions for pediatric asthmatics in public housing. Soc Sci Med. 2006 Oct;63(8):2191–203. Also available: http://dx.doi.org/10.1016/j.socscimed.2006.05.006. PMID: 16781807.16781807
38 Shirai T, Matsui T, Suzuki K, . Effect of pet removal on pet allergic asthma. Chest. 2005 May;127(5):1565–71. PMID: 15888829.15888829
39 Barnes CS, Kennedy K, Gard L, . The impact of home cleaning on quality of life for homes with asthmatic children. Allergy Asthma Proc. 2008 Mar–Apr;29(2):197–204. Also available: http://dx.doi.org/10.2500/aap.2008.29.3099. PMID: 18336723.18336723
40 Matsui EC, Perzanowski M, Peng RD, . Effect of an integrated pest management intervention on asthma symptoms among mouse-sensitized children and adolescents with asthma: a randomized clinical trial. JAMA. 2017 Mar 14;317(10):1027–36. Also available: http://dx.doi.org/10.1001/jama.2016.21048. PMID: 28264080.28264080
41 DiMango E, Serebrisky D, Narula S, . Individualized household allergen intervention lowers allergen level but not asthma medication use: a randomized controlled trial. J Allergy Clin Immunol Pract. 2016 Jul–Aug;4(4):671–679.e4. Also available: http://dx.doi.org/10.1016/j.jaip.2016.01.016. PMID: 27025297.27025297
42 Shani Z, Scott RG, Schofield LS, . Effect of a home intervention program on pediatric asthma in an environmental justice community. Health Promot Pract. 2015 Mar;16(2):291–8. Also available: http://dx.doi.org/10.1177/1524839914529593. PMID: 24733733.24733733
43 Breysse J, Dixon S, Gregory J, . Effect of weatherization combined with community health worker in-home education on asthma control. Am J Public Health. 2014 Jan;104(1):e57. Also available: http://dx.doi.org/10.2105/AJPH.2013.301402.
44 Turcotte DA, Alker H, Chaves E, . Healthy homes: in-home environmental asthma intervention in a diverse urban community. Am J Public Health. 2014 Apr;104(4):665–71. Also available: http://dx.doi.org/10.2105/AJPH.2013.301695. PMID: 24524511.24524511
45 Sweet L, Polivka BJ, Chaudry RV, . The impact of an urban home-based intervention program on asthma outcomes in children. Public Health Nurs. 2014 May;31(3):243–53. Also available: http://dx.doi.org/10.1111/phn.12071.24720657
46 El-Ghitany EM, El-Salam MM. Environmental intervention for house dust mite control in childhood bronchial asthma. Environ Health Prevent Med. 2012 Sep;17(5):377–84. Also available: http://dx.doi.org/10.1007/s12199-011-0263-5. PMID: 22302565.22302565
47 Takaro TK, Krieger J, Song L, . The Breathe-Easy Home: the impact of asthma-friendly home construction on clinical outcomes and trigger exposure. Am J Public Health. 2011 Jan;101(1):55–62. PMID: 21148715.21148715
48 Bryant-Stephens T, Kurian C, Guo R, . Impact of a household environmental intervention delivered by lay health workers on asthma symptom control in urban, disadvantaged children with asthma. Am J Public Health. 2009 Nov;(99 Suppl 3):S657–65. PMID: 19890172.19890172
49 Krieger J, Takaro TK, Song L, . A randomized controlled trial of asthma self-management support comparing clinic-based nurses and in-home community health workers: the Seattle-King County Healthy Homes II Project. Arch Pediatr Adolesc Med. 2009 Feb;163(2):141–9. Also available: http://dx.doi.org/10.1001/archpediatrics.2008.532. PMID: 19188646.19188646
50 Bryant-Stephens T, Li Y. Outcomes of a home-based environmental remediation for urban children with asthma. J Natl Med Assoc. 2008 Mar;100(3):306–16. PMID: 18390024.18390024
51 Parker EA, Israel BA, Robins TG, . Evaluation of community action against asthma: a community health worker intervention to improve children’s asthma-related health by reducing household environmental triggers for asthma. Health Educ Behav. 2008 Jun;35(3):376–95. Also available: http://dx.doi.org/10.1177/1090198106290622. PMID: 17761540.17761540
52 Burr ML, Matthews IP, Arthur RA, . Effects on patients with asthma of eradicating visible indoor mould: a randomised controlled trial. Thorax. 2007 Sep;62(9):767–72. Also available: http://dx.doi.org/10.1136/thx.2006.070847. PMID: 17389753.17389753
53 Kercsmar CM, Dearborn DG, Schluchter M, . Reduction in asthma morbidity in children as a result of home remediation aimed at moisture sources. Environ Health Perspect. 2006 Oct;114(10):1574–80. Also available: http://dx.doi.org/10.1289/ehp.8742. PMID: 17035145.17035145
54 Williams SG, Brown CM, Falter KH, . Does a multifaceted environmental intervention alter the impact of asthma on inner-city children? J Natl Med Assoc. 2006 Feb;98(2):249–60. PMID: 16708511.16708511
55 Eggleston PA, Butz A, Rand C, . Home environmental intervention in inner-city asthma: a randomized controlled clinical trial. Ann Allergy Asthma Immunol. 2005 Dec;95(6):518–24. PMID: 16400889.16400889
56 Krieger JW, Takaro TK, Song L, . The Seattle-King County Healthy Homes Project: a randomized, controlled trial of a community health worker intervention to decrease exposure to indoor asthma triggers. Am J Public Health. 2005 Apr;95(4):652–9. Also available: http://dx.doi.org/10.2105/AJPH.2004.042994. PMID: 15798126.15798126
57 Morgan WJ, Crain EF, Gruchalla RS, . Results of a home-based environmental intervention among urban children with asthma. N Engl J Med. 2004 Sep 9;351(11):1068–80. Also available: http://dx.doi.org/10.1056/NEJMoa032097. PMID: 15356304.15356304
58 Pongracic JA, Visness CM, Gruchalla RS, . Effect of mouse allergen and rodent environmental intervention on asthma in inner-city children. Ann Allergy Asthma Immunol. 2008 Jul;101(1):35–41. PMID: 18681082.18681082
59 Carter MC, Perzanowski MS, Raymond A, . Home intervention in the treatment of asthma among inner-city children. J Allergy Clin Immunol. 2001;108(5):732–7. Also available: http://dx.doi.org/10.1067/mai.2001.119155. PMID: 11692097.11692097
60 Htut T, Higenbottam TW, Gill GW, . Eradication of house dust mite from homes of atopic asthmatic subjects: a double-blind trial. J Allergy Clin Immunol. 2001;107(1):55–60. Also available: http://dx.doi.org/10.1067/mai.2001.111240. PMID: 11149991.11149991
61 Warner JA, Frederick JM, Bryant TN, . Mechanical ventilation and high-efficiency vacuum cleaning: a combined strategy of mite and mite allergen reduction in the control of mite-sensitive asthma. J Allergy Clin Immunol. 2000;105(1):75–82. PMID: 10629456.10629456
62 Cloosterman SG, Schermer TR, Bijl-Hofland ID, . Effects of house dust mite avoidance measures on Der p 1 concentrations and clinical condition of mild adult house dust mite-allergic asthmatic patients, using no inhaled steroids. Clin Exp Allergy. 1999;29(10):1336–46. Also available: http://dx.doi.org/10.1046/j.1365-2222.1999.00627.x. PMID: 10520054.10520054
63 Evans R III, Gergen PJ, Mitchell H, . A randomized clinical trial to reduce asthma morbidity among inner-city children: results of the National Cooperative Inner-City Asthma Study. J Pediatr. 1999 Sep;135(3):332–8. PMID: 10484799.10484799
64 Shapiro GG, Wighton TG, Chinn T, . House dust mite avoidance for children with asthma in homes of low- income families. J Allergy Clin Immunol. 1999;103(6):1069–74. Also available: http://dx.doi.org/10.1016/S0091-6749(99)70181-8. PMID: 10359888.10359888
65 Hayden ML, Perzanowski M, Matheson L, . Dust mite allergen avoidance in the treatment of hospitalized children with asthma. Ann Allergy Asthma Immunol. 1997;79(5):437–42. PMID: 9396978.9396978
66 Carswell F, Birmingham K, Oliver J, . The respiratory effects of reduction of mite allergen in the bedrooms of asthmatic children - a double-blind controlled trial. Clin Exp Allergy. 1996;26(4):386–96. Also available: http://dx.doi.org/10.1111/j.1365-2222.1996.tb00554.x. PMID: 8732235.8732235
67 Marks GB, Tovey ER, Green W, . House dust mite allergen avoidance: a randomized controlled trial of surface chemical treatment and encasement of bedding. Clin Exp Allergy. 1994;24(11):1078–83. Also available: http://dx.doi.org/10.1111/j.1365-2222.1994.tb02746.x. PMID: 7677828.7677828
68 Walshaw MJ, Evans CC. Allergen avoidance in house dust mite sensitive adult asthma. QJM. 1986;58(226):199–215. PMID: 3520626.3520626
69 Korsgaard J. Preventive measures in mite asthma. A controlled trial. Allergy. 1983 Feb;38(2):93–102. PMID: 6342456.6342456
70 Burr ML, Dean BV, Merrett TG, . Effects of anti-mite measures on children with mite-sensitive asthma: a controlled trial. Thorax. 1980 Jul;35(7):506–12. PMID: 7001667.7001667