# Appendix B Excluded Studies

Belice PJ, Becker EA. Effective education parameters for trigger remediation in underserved children with asthma: a systematic review. J Asthma. 2016 Jun 15;1–16. Also available: http://dx.doi.org/10.1080/02770903.2016.1198374. PMID: 27304997. Does not address Key Question27304997
Jassal MS, Diette GB, Dowdy DW. Cost-consequence analysis of multimodal interventions with environmental components for pediatric asthma in the state of Maryland. J Asthma. 2013 Aug;50(6):672–80. Also available: http://dx.doi.org/10.3109/02770903.2013.792351. PMID: 23614791. Does not address Key Question23614791
Sauni R, Uitti J, Jauhiainen M, . Remediating buildings damaged by dampness and mould for preventing or reducing respiratory tract symptoms, infections and asthma (Review). Evidence-Based Child Health. 2013 May;8(3):944–1000. Also available: http://dx.doi.org/10.1002/ebch.1914. PMID: 23877912. Does not address Key Question23877912
Singh M, Jaiswal N. Dehumidifiers for chronic asthma. Cochrane Database Syst Rev. 2013;(6):CD003563. PMID: 23760885. Does not address Key Question23760885
Lanphear BP, Hornung RW, Khoury J, . Effects of HEPA air cleaners on unscheduled asthma visits and asthma symptoms for children exposed to secondhand tobacco smoke. Pediatrics. 2011 Jan;127(1):93–101. Also available: http://dx.doi.org/10.1542/peds.2009-2312. PMID: 21149427. Irritant (smoke) not in scope21149427
Townsend KJ, George M. What is the evidence that environmental remediation programs are effective in urban children with allergic asthma? An integrated review. J Asthma Allergy Educ. 2011 Dec;2(6):295-305. Also available: http://dx.doi.org/10.1177/2150129711418826. Does not address Key Question
Krieger J, Jacobs DE, Ashley PJ, . Housing interventions and control of asthma-related indoor biologic agents: a review of the evidence. J Public Health Manag Pract. 2010 Sep–Oct;16(5 Suppl):S11–20. PMID: 20689369. Systematic review20689369
Tzeng LF, Chiang LC, Hsueh KC, . A preliminary study to evaluate a patient-centred asthma education programme on parental control of home environment and asthma signs and symptoms in children with moderate-to-severe asthma. J Clin Nurs. 2010 May;19(9):1424–33. PMID: 20500352. Education only20500352
Buczylko K, Korzycka-Zaborowska B, Michalak A. Influence of the acaricide - set on the improvement of mite allergy symptoms. Alergia Astma Immunologia. 2008 Mar;13(1):42–52. Does not provide adequate data on asthma outcomes or allergen outcomes
Gotzsche PC, Johansen HK. House dust mite control measures for asthma. Cochrane Database Syst Rev. 2008;(2):CD001187 Also available: http://dx.doi.org/10.1002/14651858.CD001187.pub3. PMID: 18425868. Systematic review18425868
Howden-Chapman P, Pierse N, Nicholls S, . Effects of improved home heating on asthma in community dwelling children: Randomised controlled trial. BMJ. 2008 Oct 11;337(7674):852–5. Also available: http://dx.doi.org/10.1136/bmj.a1411. PMID: 18812366. Does not focus on allergen removal18812366
Shedd AD, Peters JI, Wood P, . Impact of home environment characteristics on asthma quality of life and symptom scores. J Asthma. 2007 Apr;44(3):183–7. Also available: http://dx.doi.org/10.1080/02770900701209699. PMID: 17454335. Not an RCT17454335
Bernstein JA, Bobbitt RC, Levin L, . Health effects of ultraviolet irradiation in asthmatic children’s homes. J Asthma. 2006 May;43(4):255–62. Also available: http://dx.doi.org/10.1097/01.ede.0000209440.94875.42. PMID: 16809237. Due to carry over effects, data analysis focused on the first treatment period; n<1016809237
Takaro TK, Krieger JW, Song L. Effect of environmental interventions to reduce exposure to asthma triggers in homes of low-income children in Seattle. J Expo Anal Environ Epidemiol. 2004;14 Suppl 1:S133–43. Also available: http://dx.doi.org/10.1038/sj.jea.7500367. PMID: 15118754. Nonclinical data from Krieger study15118754
Hasan RA, Zureikat GY, Camp J, . The positive impact of a disease management program on asthma morbidity in inner-city children. Pediatr Asthma Allergy Immunol. 2003 Sep;16(3):147–54. Only education
Kilburn S, Lasserson TJ, McKean M. Pet allergen control measures for allergic asthma in children and adults. Cochrane Database Syst Rev. 2001;CD002989. PMID: 12535446. Systematic review12535446
Rijssenbeek Nouwens LH, Oosting AJ, De Monchy JG, . The effect of anti-allergic mattress encasings on house dust mite-induced early- and late-airway reactions in asthmatic patients. A double-blind, placebo-controlled study. Clin Exp Allergy. 2002;32(1):117–25. Also available: http://dx.doi.org/10.1046/j.0022-0477.2001.01256.x. PMID: 12002728. Preliminary report of included study^1^12002728
Singh M, Bara A, Gibson P. Humidity control for chronic asthma. Cochrane database of systematic reviews. 2002. PMID: 12076485. Does not address Key Question12076485
Gotzsche PC, Hammarquist C, Burr M. House dust mite control measures in the management of asthma: Meta-analysis. Br Med J. 1998 Oct 24;317(7166):1105–10. PMID: 9784442. Systematic review9784442
Wood RA, Johnson EF, Van Natta ML, . A placebo-controlled trial of a HEPA air cleaner in the treatment of cat allergy. Am J Respir Crit Care Med. 1998;158(1):115–20. PMID: 9655716. <85% patients with asthma, data not reported separately9655716
Ehnert B, Lau-Schadendorf S, Weber A, . Reducing domestic exposure to dust mite allergen reduces bronchial hyperreactivity in sensitive children with asthma. J Allergy Clin Immunol. 1992 Jul;90(1):135–8. PMID: 1629503. Fewer than 10 patients enrolled1629503

## Reference List for Appendix B

1 Rijssenbeek-Nouwens LH, Oosting AJ, de Bruin-Weller MS, . Clinical evaluation of the effect of anti-allergic mattress covers in patients with moderate to severe asthma and house dust mite allergy: a randomised double blind placebo controlled study. Thorax. 2002 Sep;57(9):784–90. Also available: http://dx.doi.org/10.1136/thorax.57.9.784. PMID: 12200523.12200523