# Appendix A Search Strategies

## Resources Searched

ECRI Institute information specialists searched the following databases for relevant information. Search terms and strategies for each resource appear below.

Table A-1 Databases searched

Name | Date Limits | Platform/Provider
The Cochrane Central Register of Controlled Trials (CENTRAL) | Inception [1999] through April 21, 2017 | Wiley
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Inception [1999] through April 21, 2017 | Wiley
Cumulative Index of Nursing and Allied Health Literature (CINAHL) | Inception [1981] through April 21, 2017 | EBSCOhost
Database of Abstracts of Reviews of Effects (DARE) (part of the Cochrane Library) | Inception [1999] through April 21, 2017 | Wiley
EMBASE (Excerpta Medica) | Inception [1966] through April 21, 2017 | Embase.com
Health Technology Assessment Database (HTA) (part of the Cochrane Library) | Inception [1999] through April 21, 2017 | Wiley
MEDLINE | Inception [1966] through April 21, 2017 | Embase.com
PUBMED (In Process citations) | Inception [1966] through April 21, 2017 | NLM
U.K. National Health Service Economic Evaluation Database (NHS EED) (part of the Cochrane Library) | Inception [1999] through April 21, 2017 | Wiley
Associations and Societies
American Academy of Allergy, Asthma, and Immunology | June 29, 2016 | https://www.aaaai.org/
Asthma and Allergy Foundation of America | June 30, 2016 | http://www.aafa.org/
American Academy of Pediatrics | June 30, 2016 | https://www.aap.org
American College of Allergy, Asthma, and Immunology | June 29, 2016 | http://acaai.org/
Agency for Healthcare Research and Quality Technology Assessment Program | June 29, 2016 | http://www.ahrq.gov/research/findings/ta/index.html
American Lung Association | June 29, 2016 | http://www.lung.org/
American Public Health Association | June 29, 2016 | https://www.apha.org/
American Thoracic Society | June 29, 2016 | https://www.thoracic.org/
Centers for Disease Control and Prevention | June 28, 2016 | https://www.cdc.gov/
Children’s Health Protection Advisory Committee | June 30, 2016 | https://www.epa.gov/children/childrens-health-protection-advisory-committee-chpac
Global Initiative for Asthma | June 30, 2016 | http://ginasthma.org/
National Center for Healthy Housing | June 30, 2016 | http://www.nchh.org/
National Academy of Medicine | June 28, 2016 | https://nam.edu/
National Environmental Education Foundation | June 30, 2016 | https://www.neefusa.org/
National Heart, Lung, and Blood Institute | June 30, 2016 | https://www.nhlbi.nih.gov/
United States Environmental Protection Agency | June 28, 2016 | https://www3.epa.gov/
United States National Institute of Environmental Health Sciences | June 29, 2016 | http://www.niehs.nih.gov/
Other Gray Literature Resources
ClinicalTrials.gov | Searched August 1, 2016 | NIH
Centers for Medicare and Medicaid (CMS) - Medicare Coverage Database | Searched August 2, 2016 | CMS
ECRI Institute Library Catalog | Searched August 2, 2016 | ECRI Institute
ECRI Institute Members Website | Searched August 2, 2016 | ECRI Institute
Health Devices | Searched August 2, 2016 | ECRI Institute
Healthcare Standards | Searched August 1, 2016 | ECRI Institute
Internet | Searched August 3, 2016 | Google; Bing
Medscape | Searched June 22, 2016 | WebMD
National Guideline Clearinghouse™ | Searched August 1, 2016 | AHRQ
National Institute for Health and Care Excellence, U.K. | Searched August 1, 2016 | NHS
TRIP (Turning Research Into Practice) Database | Searched August 4, 2016 | Trip Database, Ltd.
U.S. Food and Drug Administration (FDA), including Medical Device databases | Searched August 1, 2016 | FDA

### Reimbursement

The following Web sites were searched for reimbursement policies: Aetna, Anthem BCBS, BCBS Florida, BCBS of Illinois, BCBS of Texas, BCBS of California, CIGNA, Humana, United Healthcare, Regence.

## Hand Searches of Journal and Gray Literature

Journals and supplements maintained in ECRI Institute’s collections were routinely reviewed. Nonjournal publications from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

## Topic-Specific Search Terms

The search strategies employed combinations of free-text keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. Strategies for each bibliographic database follow this table.

Table A-2 Topic-specific search terms

Concept | Controlled Vocabulary | Keywords
Asthma | EMBASE (EMTREE) asthma/exp ‘allergic asthma’/exp ‘asthmatic state’/exp ‘extrinsic asthma’/exp ‘intrinsic asthma’/exp ‘mild intermittent asthma’/exp ‘mild persistent asthma’/exp ‘nocturnal asthma’/exp ‘occupational asthma’/exp ‘severe persistent asthma’/exp MEDLINE/PubMed(MeSH) Asthma[mh] CINAHL (MH “Asthma+”) (MH “Asthma, Occupational”) | Asthma*
General Allergy terms | EMBASE (EMTREE) allergen/exp ‘disease exacerbation’/exp ‘environmental exposure’/exp ‘health hazard’/exp MEDLINE/PubMed (MeSH) Allergens[mh] “environmental exposure”[mh] CINAHL (MH “Allergens+”) (MH “Disease Exacerbation”) (MH “Environmental Exposure+”) | Allergen exacerbation exacerbate irritant sensitive sensitivity trigger
Environmental and Household Allergens | EMBASE (EMTREE) ‘airborne particle’/exp cat/exp cockroach/exp dander/exp dog/exp dust/exp household/exp mite/exp mould/exp ‘pest insect’/exp ‘pest organism’/exp ‘pest rodent’/exp ‘pet animal’/exp MEDLINE/PubMed (MeSH) “antigens, dermatophagoides”[mh] cats[mh] cockroaches[mh] dander[mh] “dermatophagoides farina”[mh] “dermatophagoides pteronyssinus”[mh] dogs[mh] dust[mh] fungi[mh] mites[mh] “mite infestations”[mh] pets[mh] “particulate matter”[mh] CINAHL (MH “Cats”) (MH “Cockroaches”) (MH “Dogs”) (MH “Dust”) (MH “Fungi+”) (MH “Mites”) (MH “Pets”) | apartment cat cats chalk cockroach damp dander dermatophagoides daycare dog dogs dust dust mites fungus fungi home house housing housedust indoor insect mice mite mites moisture mold moldy mould mouldy mouse pet pets pest pests residence residential roach rodent school
Environmental Interventions | EMBASE (EMTREE) ‘air filter’/exp bed/exp cleaning/exp ‘environmental sanitation’/exp ‘risk reduction’/exp vacuum/exp ‘pests and pest control’/exp ‘pest control’/exp ‘indoor residual spraying’/exp MEDLINE/PubMed (MeSH) “air filters”[mh] beds[mh] housekeeping[mh] “insect control”[mh] sanitation[mh] vacuum[mh] “pest control”[mh] “rodent control”[mh] ventilation[mh] CINAHL (MH “Air Filters”) (MH “Beds and Mattresses+”) (MH “Home Maintenance”) (MH “Pest Control”) (MH “Sanitation+”) (MH “Vacuum”) (MH “Ventilation+”) | air filter air filtration air purification allergen reduction bath bathe bathing bed beds bedding clean cleaning comforter cover covering covers dehumidifier dehumidify duct cleaning duvet encase exterminate fabric feather futon HEPA high efficiency particulate arrestance hypoallergenic insulation launder laundering laundry linen mattress pet removal pet bathing pillow reduce sanitation sanitize sheet spray spraying sun sunlight remove removal vacuum ventilation wash washing wipe wiping
Carpet/Flooring | EMBASE (EMTREE) building/exp MEDLINE/PubMed (MeSH) “Floors and floorcoverings”[mh] CINAHL (MH “Floors and Floorcoverings”) | carpet* floor* rug rugs wood*

## Search Strategies

### Embase/Medline

Table A-3 Embase/MEDLINE

Set Number | Concept | Search Statement
1 | Asthma | asthma/exp OR ‘allergic asthma’/exp OR ‘asthmatic state’/exp OR ‘extrinsic asthma’/exp OR ‘intrinsic asthma’/exp OR ‘mild intermittent asthma’/exp OR ‘mild persistent asthma’/exp OR ‘nocturnal asthma’/exp OR ‘occupational asthma’/exp OR ‘severe persistent asthma’/exp OR asthma*:ti,ab,de
2 | Environmental Allergens | ((‘allergen’/exp OR ‘environmental exposure’/exp OR ‘health hazard’/exp OR ‘disease exacerbation’/exp OR allerg* OR irritant* OR trigger* OR exacerbat* OR sensitiv*) AND (‘airborne particle’/exp OR ‘cat’/exp OR ‘cockroach’/exp OR ‘dander’/exp OR ‘dog’/exp OR ‘dust’/exp OR ‘household’/exp OR ‘mite’/exp OR ‘mould’/exp OR ‘pest insect’/exp OR ‘pest organism’/exp OR ‘pest rodent’/exp OR ‘pet animal’/exp OR cat OR cats OR cockroach* OR housedust* OR roach* OR damp* OR dander OR dermatophagoide* OR daycare OR dog OR dogs OR dust* OR home* OR house* OR indoor* OR insect* OR mite OR mites OR mold OR mould OR moldy OR mouldy OR mouse OR mice OR pet OR pets OR pest OR pests OR rodent* OR school* OR moist* OR fungus OR fungi OR chalk*))
2 | Household Allergens | OR ((‘household’/exp OR daycare OR home* OR house* OR indoor* OR residence OR residential OR apartment* OR housing) AND (‘airborne particle’/exp OR ‘cat’/exp OR ‘cockroach’/exp OR ‘dander’/exp OR ‘dog’/exp OR ‘dust’/exp OR ‘mite’/exp OR ‘mould’/exp OR ‘pest insect’/exp OR ‘pest organism’/exp OR ‘pest rodent’/exp OR ‘pet animal’/exp OR cat OR cats OR cockroach* OR housedust* OR roach* OR damp* OR dander OR dermatophagoide* OR dog OR dogs OR dust* OR insect* OR mite OR mites OR mold OR mould OR moldy OR mouldy OR mouse OR mice OR pet OR pets OR pest OR pests OR rodent* OR school* OR moist* OR fungus OR fungi OR chalk*))
3 | Environmental Interventions | (‘air filter’/exp OR bed/exp OR cleaning/exp OR ‘environmental sanitation’/exp OR vacuum/exp OR ‘pests and pest control’/exp OR ‘pest control’/exp OR ‘indoor residual spraying’/exp) OR (air NEAR/2 (clean* OR filter* OR filtrat* OR purif*)) OR ventilat* OR insulat* OR (duct* NEAR/2 clean*) OR dehumid* OR bed OR beds OR bedding OR futon* OR clean* OR comforter* OR cover OR covers OR covering* OR duvet* OR encase* OR feather* OR linen* OR fabric OR pillow* OR mattress* OR sanita* OR sanitis* OR sanitiz* OR sheet* OR vacuum* OR sun OR sunlight* OR hypoallergenic OR remove OR removal OR bath* OR exterminat* OR spray* OR ((allergen OR pet OR pets OR pest*) NEAR/5 (reduc* OR avoid* OR eliminat*)) OR wipe OR wiping OR launder OR laundering OR laundry OR hepa OR ‘high-efficiency particulate arrestance’ OR ‘high efficiency particulate arrestance’ OR wash OR washing
4 | Carpet/Flooring Removal | building/exp OR (carpet* OR floor* OR rug OR rugs OR wood*):ab,ti,de
5 | Combine sets | 1 AND 2 AND 3
6 | Combine sets | 1 AND 4
7 | Combine sets | 5 OR 6
8 | Remove unwanted publication types | 7 NOT (abstract:nc OR annual:nc OR book/de OR ‘case report’/de OR ‘case study’/de OR conference:nc OR ‘conference abstract’:it OR ‘conference paper’/de OR ‘conference paper’:it OR ‘conference proceeding’:pt OR ‘conference review’:it OR congress:nc OR editorial/de OR editorial:it OR erratum/de OR letter:it OR note/de OR note:it OR meeting:nc OR sessions:nc OR ‘short survey’/de OR symposium:nc)
9 | Controlled study filter | 8 AND (‘randomized controlled trial’/exp OR ‘randomized controlled trial’ OR ‘randomization’/exp OR ‘randomization’ OR ‘double blind procedure’/exp OR ‘double blind procedure’ OR ‘single blind procedure’/exp OR ‘single blind procedure’ OR ‘placebo’/exp OR ‘placebo’ OR ‘latin square design’/exp OR ‘latin square design’ OR ‘crossover procedure’/exp OR ‘crossover procedure’ OR ‘triple blind procedure’/exp OR ‘triple blind procedure’ OR ‘controlled study’/exp OR ‘controlled study’ OR ‘clinical trial’/exp OR ‘clinical trial’ OR ‘comparative study’/exp OR ‘comparative study’ OR ‘cohort analysis’/exp OR ‘cohort analysis’ OR ‘follow up’/exp OR ‘follow up’ OR ‘intermethod comparison’/exp OR ‘intermethod comparison’ OR ‘parallel design’/exp OR ‘parallel design’ OR ‘control group’/exp OR ‘control group’ OR ‘prospective study’/exp OR ‘prospective study’ OR ‘retrospective study’/exp OR ‘retrospective study’ OR ‘case control study’/exp OR ‘case control study’ OR ‘major clinical study’/exp OR ‘major clinical study’ OR ‘evaluation study’/exp OR ‘evaluation study’ OR random*:de OR random*:ti OR placebo* OR (singl* OR doubl* OR tripl* OR trebl* AND (dummy OR ‘blind’/exp OR blind OR sham)) OR ‘latin square’ OR isrctn* OR actrn* OR (nct* NOT nct))
10 | Systematic Review/Meta-analysis filter | 8 AND (‘research synthesis’ OR pooled OR ‘systematic review’/exp OR ‘systematic review’ OR ‘meta analysis’/exp OR ‘meta analysis’ OR ((‘evidence base’ OR ‘evidence based’/exp OR ‘evidence based’ OR methodol* OR systematic OR quantitative* OR studies OR search*) AND (‘review’/exp OR ‘review’ OR ‘review’/it)))
11 | Combine Sets | 9 OR 10
12 | Apply Limits | 11 AND (‘human’/de OR [adolescent]/lim OR [adult]/lim OR [aged]/lim OR [child]/lim OR [infant]/lim OR [middle aged]/lim OR [newborn]/lim OR [preschool]/lim OR [school]/lim OR [very elderly]/lim OR [young adult]/lim)

#### EMBASE.com Syntax

* | = | truncation character (wildcard)
NEAR/n | = | search terms within a specified number (n) of words from each other in any order
NEXT/n | = | search terms within a specified number (n) of words from each other in the order specified
/ | = | search as a subject heading
exp | = | “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy)
mj | = | denotes a term that has been searched as a major subject heading
:de | = | search in the descriptors field (controlled terms and keywords)
:lnk | = | floating subheading
/lim | = | limiter
:it,pt. | = | source item or publication type
:ti. | = | limit to title
:ti,ab. | = | limit to title and abstract fields

### PubMed (PreMEDLINE)

Table A-4 PubMed in process citations

Set Number | Concept | Search Statement
1 | Asthma[mh] OR asthma* | Asthma[mh] OR asthma*
2 | Environmental Allergens | (“Allergens”[Mesh] OR “Environmental Exposure”[Mesh] OR allerg*[tiab] OR irritant*[tiab] OR trigger*[tiab] OR exacerbat*[tiab] OR sensitiv*[tiab]) AND (“Particulate Matter”[Mesh] OR “Cats”[Mesh] OR “Dander”[Mesh] OR “Dogs”[Mesh] OR “Cockroaches”[Mesh] OR “Dust”[Mesh] OR “Antigens, Dermatophagoides”[Mesh] OR “Dermatophagoides pteronyssinus”[Mesh] OR “Dermatophagoides farinae”[Mesh] OR “Mites”[Mesh] OR “Mite Infestations”[Mesh] OR “Fungi”[Mesh] OR “Pets”[Mesh] OR cat[tiab] OR cats[tiab] OR cockroach*[tiab] OR housedust*[tiab] OR roach*[tiab] OR damp*[tiab] OR dander[tiab] OR dermatophagoide*[tiab] OR daycare[tiab] OR dog[tiab] OR dogs[tiab] OR dust*[tiab] OR home*[tiab] OR house*[tiab] OR indoor*[tiab] OR insect*[tiab] OR mite[tiab] OR mites[tiab] OR mold[tiab] OR mould[tiab] OR moldy[tiab] OR mouldy[tiab] OR mouse[tiab] OR mice[tiab] OR pet[tiab] OR pets[tiab] OR pest[tiab] OR pests[tiab] OR rodent*[tiab] OR school*[tiab] OR moist*[tiab] OR fungus[tiab] OR fungi[tiab] OR chalk*[tiab])
2 | Household Allergens | OR (daycare OR home* OR house* OR indoor* OR residence OR residential OR apartment* OR housing) AND(“Particulate Matter”[Mesh] OR “Cats”[Mesh] OR “Dander”[Mesh] OR “Dogs”[Mesh] OR “Cockroaches”[Mesh] OR “Dust”[Mesh] OR “Antigens, Dermatophagoides”[Mesh] OR “Dermatophagoides pteronyssinus”[Mesh] OR “Dermatophagoides farinae”[Mesh] OR “Mites”[Mesh] OR “Mite Infestations”[Mesh] OR “Fungi”[Mesh] OR “Pets”[Mesh] OR cat[tiab] OR cats[tiab] OR cockroach*[tiab] OR housedust*[tiab] OR roach*[tiab] OR damp*[tiab] OR dander[tiab] OR dermatophagoide*[tiab] OR dog[tiab] OR dogs[tiab] OR dust*[tiab] OR insect*[tiab] OR mite[tiab] OR mites[tiab] OR mold[tiab] OR mould[tiab] OR moldy[tiab] OR mouldy[tiab] OR mouse[tiab] OR mice[tiab] OR pet[tiab] OR pets[tiab] OR pest[tiab] OR pests[tiab] OR rodent*[tiab] OR school*[tiab] OR moist*[tiab] OR fungus[tiab] OR fungi[tiab] OR chalk*[tiab])
3 | Environmental Interventions | “Air Filters”[Mesh] OR “Beds”[Mesh] OR “Housekeeping”[Mesh] OR “Sanitation”[Mesh] OR “Vacuum”[Mesh] OR “Pest Control”[Mesh] OR “Insect Control”[Mesh] OR “Rodent Control”[Mesh] OR ventilation[Mesh] OR (air[tiab] AND (clean*[tiab] OR filter*[tiab] OR filtrat*[tiab] OR purif*[tiab])) OR ventilat*[tiab] OR insulat*[tiab] OR (duct*[tiab] AND clean*[tiab]) OR dehumid*[tiab] OR bed*[tiab] OR futon*[tiab] OR clean*[tiab] OR comforter*[tiab] OR cover[tiab] OR covers[tiab] OR covering*[tiab] OR duvet*[tiab] OR encase*[tiab] OR feather*[tiab] OR linen*[tiab] OR fabric[tiab] OR pillow*[tiab] OR mattress*[tiab] OR sanita*[tiab] OR sanitis*[tiab] OR sanitiz*[tiab] OR sheet*[tiab] OR vacuum*[tiab] OR hypoallergenic*[tiab] OR exterminat*[tiab] OR spray*[tiab] OR sun[tiab] [tiab] OR sunlight*[tiab] OR bath*[tiab] OR ((allergen*[tiab] OR pet[tiab] OR pets[tiab] OR pest*[tiab]) AND (reduc*[tiab] OR avoid*[tiab] OR eliminat*[tiab] OR remove OR removal)) OR wipe[tiab] OR wiping[tiab] OR launder[tiab] OR laundering[tiab] OR laundry[tiab] OR hepa[tiab] OR ‘high-efficiency particulate arrestance’[tiab] OR ‘high efficiency particulate arrestance’[tiab] OR wash[tiab] OR washing[tiab]
4 | Carpet/Flooring removal | “Floors and Floorcoverings”[Mesh] OR (carpet*[tiab] OR floor*[tiab] OR rug[tiab] OR rugs[tiab] OR wood*[tiab])
5 | Combine sets | 1 AND 2 AND 3
6 | Combine sets | 1 AND 4
7 | Combine sets | 5 OR 6
8 | Remove unwanted publication types | 7 NOT (case reports[pt] OR comment[pt] OR editorial[pt] OR letter[pt] OR news[pt] OR “Textbooks” [pt] OR “Book Reviews”[pt]OR “Book Illustrations”[pt] OR book OR books OR textbook*)
9 | In process citations | 8 AND (“inprocess”[sb] OR publisher[sb] OR pubmednotmedline[sb])

#### PubMed Syntax

* | = | truncation character (wildcard)
[mh]/[MesH] | = | controlled vocabulary term
[sb] | = | subset
[ti] | = | limit to title field
[tiab] | = | limit to title and abstract fields
[tw] | = | text word

### CINAHL

English language, human, exclude MEDLINE records

Table A-5 CINAHL

Set Number | Concept | Search Statement
1 | Asthma | (MH “Asthma+”) OR (MH “Asthma, Occupational”) OR asthma*
2 | Household allergens | ((MH “Allergens+”) OR (MH “Disease Exacerbation”) OR (MH “Environmental Exposure+”) OR allerg* OR irritant* OR trigger* OR exacerbat* OR sensitiv*) AND ((MH “Dogs”) OR (MH “Cats”) OR (MH “Pets”) OR (MH “Cockroaches”) OR (MH “Dust”) OR (MH “Mites”) OR (MH “Fungi+”) OR cat OR cats OR cockroach* OR housedust* OR roach* OR damp* OR dander OR dermatophagoide* OR daycare OR dog OR dogs OR dust* OR home* OR house* OR indoor* OR insect* OR mite OR mites OR mold OR mould OR moldy OR mouldy OR mouse OR mice OR pet OR pets OR pest OR pests OR rodent* OR school* OR moist* OR fungus OR fungi OR chalk*)
3 | Environmental Interventions/Household Allergens | ((MH “Air Filters”) OR (MH “Beds and Mattresses+”) OR (MH “Home Maintenance”) OR (MH “Sanitation+”) OR (MH “Vacuum”) OR (MH “Pest Control”) OR (MH “Ventilation+”) OR (air AND (clean* OR filter* OR filtrat* OR purif*)) OR ventilat* OR insulat* OR (duct* AND clean*) OR dehumid* OR bed OR beds OR bedding OR futon* OR clean* OR comforter* OR cover OR covers OR covering* OR duvet* OR encase* OR feather* OR linen* OR fabric OR pillow* OR mattress* OR sanita* OR sanitis* OR sanitiz* OR sheet* OR vacuum* OR sun OR sunlight* OR hypoallergenic OR remove OR removal OR bath* OR exterminat* OR spray* OR ((allergen OR pet OR pets OR pest*) AND (reduc* OR avoid* OR eliminat*)) OR wipe OR wiping OR launder OR laundering OR laundry OR hepa OR “high-efficiency particulate arrestance” OR “high efficiency particulate arrestance” OR wash OR washing
4 | Carpet/Flooring Removal | (MH “Floors and Floorcoverings”) OR carpet* OR floor* OR rug OR rugs OR wood*
5 | Combine sets Key Question 1 | 1 AND 2 AND 3
6 | Combine sets Key Question 2 | 1 AND 4
7 | Combine sets Key Question 1 OR Key Question 2 | 5 OR 6
8 | Remove Medline records/limit to academic journals

#### CINAHL Syntax

…+ | = | explode
* | = | truncation character (wildcard)
Nn | = | search terms within a specified number (n) of words from each other in any order
TI | = | limit to title field
AB | = | limit to title and abstract fields
MH | = | MeSH heading
MJ | = | MeSH heading designated as major topic
PT | = | publication type