# Abbreviations and Acronyms

ACQ: Asthma Control Questionnaire
ACT: Asthma Control Test
AHRQ: Agency for Healthcare Research and Quality
AQLQ: Asthma Quality of Life Questionnaire
Can f 1: canis familiaris dog allergen 1
Bla g 1: blattella germanica cockroach allergen 1
CDC: Centers for Disease Control and Prevention
CHSA: Children’s Health Survey for Asthma
CI: confidence interval
Der f 1: Dermatophagoides farina dust mite allergen 1
Der p 1: Dermatophagoides pteronyssinus dust mite allergen 1
ED: emergency department
FEF_25–75_: average forced expiratory flow during the middle 25–75% portion of forced vital capacity
Fel d 1: Felis domesticus cat allergen 1
FeNO: fractional exhaled nitric oxide
FEV_1_: forced expiratory volume in one second
FVC: forced vital capacity
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HDM: house dust mite
HEPA: high-efficiency particulate air-filtration
ICS: inhaled corticosteroid
IgE: immunoglobulin E
IQR: interquartile range
mcg/g: micrograms per gram
Mini AQLQ: Mini Asthma Quality of Life Questionnaire
Mus m 1: Mus musculus mouse allergen 1
NAEPP: National Asthma Education and Prevention Program
NHLBI: National Heart, Lung, and Blood Institute
NR: not reported
OR: odds ratio
PACQLQ: Pediatric Asthma Caregiver’s Quality of Life Questionnaire
PC_20_: provocative concentration of methacholine causing a 20% drop in FEV_1_
PEFR: peak expiratory flow rate
PFV: peak flow variability
PICOTS: patient populations, interventions, comparators, outcomes, timing, and settings
RAST: radioallergosorbent test
RCT: randomized controlled trial
RR: relative risk
SD: standard deviation
SE: standard error
SEM: standard error of the mean
SGRQ: St. George’s Respiratory Questionnaire
SOE: strength of evidence
TEP: technical expert panel
u/g: units per gram