# References

1 Bush DE, Ziegelstein RC, Patel UV, . Post-myocardial infarction depression. Evid Rep Technol Assess (Summ). 2005 May(123):1–8. PMID: 15989376.15989376
2 World Health Organization. Global status report on noncommunicable diseases. 2014. Available at: http://www.who.int/nmh/publications/ncd-status-report-2014/en/. Accessed March 1, 2016.
3 Centers for Disease Control and Prevention (CDC). Deaths: Leading Causes for 2013. NVSR Volume 65, Number 2. 95 pp. (PHS) 2016–1250. Available at: http://www.cdc.gov/nchs/data/nvsr/nvsr65/nvsr65_02.pdf. Accessed March 1, 2016.
4 Blackwell DL, Lucas JW, Clarke TC. Summary health statistics for U.S. adults: national health interview survey, 2012. Vital Health Stat 10. 2014 Feb(260):1–161. PMID: 24819891.24819891
5 Centers for Disease Control and Prevention (CDC). Heart Disease Facts, 2015. Available at: http://www.cdc.gov/heartdisease/facts.htm. Accessed February 16, 2016.
6 Williams RB. Cardiology Patient Page. Depression after heart attack: why should I be concerned about depression after a heart attack? Circulation. 2011 Jun 28;123(25):e639–40. doi: 10.1161/circulationaha.110.017285. PMID: 21709066.21709066
7 Kessler RC, Berglund P, Demler O, . Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005 Jun;62(6):593–602. doi: 10.1001/archpsyc.62.6.593. PMID: 15939837.15939837
8 Guck TP, Kavan MG, Elsasser GN, . Assessment and treatment of depression following myocardial infarction. Am Fam Physician. 2001 Aug 15;64(4):641–8. PMID: 11529263.11529263
9 Thombs BD, Bass EB, Ford DE, . Prevalence of depression in survivors of acute myocardial infarction. J Gen Intern Med. 2006 Jan;21(1):30–8. doi: 10.1111/j.1525-1497.2005.00269.x. PMID: 16423120.16423120
10 Doyle F, McGee H, Conroy R, . Systematic Review and Individual Patient Data Meta-Analysis of Sex Differences in Depression and Prognosis in Persons With Myocardial Infarction: A MINDMAPS Study. Psychosom Med. 2015 May;77(4):419–28. doi: 10.1097/psy.0000000000000174. PMID: 25886829.25886829
11 Rapaport MH, Judd LL, Schettler PJ, . A descriptive analysis of minor depression. Am J Psychiatry. 2002 Apr;159(4):637–43. doi: 10.1176/appi.ajp.159.4.637. PMID: 11925303.11925303
12 Williams JW, Jr., Kerber CA, Mulrow CD, . Depressive disorders in primary care: prevalence, functional disability, and identification. J Gen Intern Med. 1995 Jan;10(1):7–12. PMID: 7699487.7699487
13 Jackson JL, Passamonti M, Kroenke K. Outcome and impact of mental disorders in primary care at 5 years. Psychosom Med. 2007 Apr;69(3):270–6. doi: 10.1097/PSY.0b013e3180314b59. PMID: 17401055.17401055
14 Pincus HA, Davis WW, McQueen LE. ‘Subthreshold’ mental disorders. A review and synthesis of studies on minor depression and other ‘brand names’. Br J Psychiatry. 1999 Apr;174:288–96. PMID: 10533546.10533546
15 Karg RS, Bose J, Batts KR, . Past Year Mental Disorders among Adults in the United States: Results from the 2008–2012 Mental Health Surveillance Study. October 2014. Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality Data Review. http://www.samhsa.gov/data/sites/default/files/NSDUH-DR-N2MentalDis-2014-1/Web/NSDUH-DR-N2MentalDis-2014.pdf. Accessed June 20, 2016.
16 Ferrari AJ, Charlson FJ, Norman RE, . Burden of depressive disorders by country, sex, age, and year: findings from the global burden of disease study 2010. PLoS Med. 2013 Nov;10(11):e1001547. doi: 10.1371/journal.pmed.1001547. PMID: 24223526.24223526
17 Gartlehner G, Gaynes BN, Amick HR, . Nonpharmacological Versus Pharmacological Treatments for Adult Patients With Major Depressive Disorder. Comparative Effectiveness Review No. 161. (Prepared by the RTI International–University of North Carolina Evidence-based Practice Center under Contract No. 290-2012-00008-I.) AHRQ Publication No. 15(16)-EHC031-EF. Rockville, MD: Agency for Healthcare Research and Quality; December 2015. www.effectivehealthcare.ahrq.gov/reports/final.cfm. PMID: 2676443826764438.
18 Lichtman JH, Froelicher ES, Blumenthal JA, . Depression as a risk factor for poor prognosis among patients with acute coronary syndrome: systematic review and recommendations: a scientific statement from the American Heart Association. Circulation. 2014 Mar 25;129(12):1350–69. doi: 10.1161/cir.0000000000000019. PMID: 24566200.24566200
19 Blumenthal JA, Waldman S, Babyak MA, . Treating depression in patients with heart disease: is the glass half empty or half full? Am Heart J. 2009 May 01;157(5):e35–e7. doi: 10.1016/j.ahj.2009.03.006. PMID: 20706603.20706603
20 Siu AL, U.S. Preventive Services Task Force, Bibbins-Domingo K, . Screening for Depression in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016 Jan 26;315(4):380–7. doi: 10.1001/jama.2015.18392. PMID: 26813211.26813211
21 National Collaborating Centre for Mental Health (UK). Depression in Adults with a Chronic Physical Health Problem: Treatment and Management. Leicester (UK): British Psychological Society; 2010. (NICE Clinical Guidelines, No. 91.) Available at: http://www.ncbi.nlm.nih.gov/books/NBK82930/. Accessed September 14, 2016. PMID: 2225982622259826.
22 Joffres M, Jaramillo A, Dickinson J, . Recommendations on screening for depression in adults. CMAJ. 2013 Jun 11;185(9):775–82. doi: 10.1503/cmaj.130403. PMID: 23670157.23670157
23 Post-Myocardial Infarction Depression Clinical Practice Guideline Panel. AAFP guideline for the detection and management of post-myocardial infarction depression. Ann Fam Med. 2009 Jan–Feb;7(1):71–9. doi: 10.1370/afm.918. PMID: 19139452.19139452
24 Lichtman JH, Bigger JT, Jr., Blumenthal JA, . Depression and coronary heart disease: recommendations for screening, referral, and treatment: a science advisory from the American Heart Association Prevention Committee of the Council on Cardiovascular Nursing, Council on Clinical Cardiology, Council on Epidemiology and Prevention, and Interdisciplinary Council on Quality of Care and Outcomes Research: endorsed by the American Psychiatric Association. Circulation. 2008 Oct 21;118(17):1768–75. doi: 10.1161/circulationaha.108.190769. PMID: 18824640.18824640
25 Hare DL, Toukhsati SR, Johansson P, . Depression and cardiovascular disease: a clinical review. Eur Heart J. 2014 Jun 1;35(21):1365–72. doi: 10.1093/eurheartj/eht462. PMID: 24282187.24282187
26 Moore RC, Chattillion EA, Ceglowski J, . A randomized clinical trial of Behavioral Activation (BA) therapy for improving psychological and physical health in dementia caregivers: results of the Pleasant Events Program (PEP). Behav Res Ther. 2013 Oct;51(10):623–32. doi: 10.1016/j.brat.2013.07.005. PMID: 23916631.23916631
27 Craft LL, Perna FM. The benefits of exercise for the clinically depressed. Prim Care Companion J Clin Psychiatry. 2004;6(3):104–11. PMID: 15361924.15361924
28 Taylor RS, Brown A, Ebrahim S, . Exercise-based rehabilitation for patients with coronary heart disease: systematic review and meta-analysis of randomized controlled trials. Am J Med. 2004 May 15;116(10):682–92. doi: 10.1016/j.amjmed.2004.01.009. PMID: 15121495.15121495
29 Blumenthal JA, Babyak MA, Carney RM, . Exercise, depression, and mortality after myocardial infarction in the ENRICHD trial. Med Sci Sports Exerc. 2004 May;36(5):746–55. PMID: 15126705.15126705
30 Blumenthal JA, Sherwood A, Babyak MA, . Exercise and pharmacological treatment of depressive symptoms in patients with coronary heart disease: results from the UPBEAT (Understanding the Prognostic Benefits of Exercise and Antidepressant Therapy) study. J Am Coll Cardiol. 2012 Sep 18;60(12):1053–63. doi: 10.1016/j.jacc.2012.04.040. PMID: 22858387.22858387
31 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD: Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed July 16, 2015.
32 Moher D, Liberati A, Tetzlaff J, . Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009 Jul 21;6(7):e1000097. doi: 10.1371/journal.pmed.1000097. PMID: 19621072.19621072
33 Ski CF, Jelinek M, Jackson AC, . Psychosocial interventions for patients with coronary heart disease and depression: A systematic review and meta-analysis. Eur J Cardiovasc Nurs. 2016 Aug;15(5):305–16. doi: 10.1177/1474515115613204. PMID: 26475227.26475227
34 Janzon E, Abidi T, Bahtsevani C. Can physical activity be used as a tool to reduce depression in patients after a cardiac event? What is the evidence? A systematic literature study. Scand J Psychol. 2015 Apr;56(2):175–81. doi: 10.1111/sjop.12190. PMID: 25756318.25756318
35 Ramamurthy G, Trejo E, Faraone SV. Depression treatment in patients with coronary artery disease: a systematic review. Prim Care Companion CNS Disord. 2013;15(5)doi: 10.4088/PCC.13r01509. PMID: 24511449.24511449
36 Colquhoun DM, Bunker SJ, Clarke DM, . Screening, referral and treatment for depression in patients with coronary heart disease. Med J Aust. 2013 May 20;198(9):483–4. PMID: 23682890.23682890
37 Whooley MA, Wong JM. Depression and cardiovascular disorders. Annu Rev Clin Psychol. 2013;9:327–54. doi: 10.1146/annurev-clinpsy-050212-185526. PMID: 23537487.23537487
38 Thombs BD, Roseman M, Coyne JC, . Does evidence support the American Heart Association’s recommendation to screen patients for depression in cardiovascular care? An updated systematic review. PLoS One. 2013;8(1):e52654. doi: 10.1371/journal.pone.0052654. PMID: 23308116.23308116
39 Mavrides N, Nemeroff C. Treatment of depression in cardiovascular disease. Depress Anxiety. 2013 Apr;30(4):328–41. doi: 10.1002/da.22051. PMID: 23293051.23293051
40 Whalley B, Rees K, Davies P, . Psychological interventions for coronary heart disease. Cochrane Database Syst Rev. 2011(8):Cd002902. doi: 10.1002/14651858.CD002902.pub3. PMID: 21833943.21833943
41 Pizzi C, Rutjes AW, Costa GM, . Meta-analysis of selective serotonin reuptake inhibitors in patients with depression and coronary heart disease. Am J Cardiol. 2011 Apr 1;107(7):972–9. doi: 10.1016/j.amjcard.2010.11.017. PMID: 21256471.21256471
42 O’Neil A, Sanderson K, Oldenburg B, . Impact of depression treatment on mental and physical health-related quality of life of cardiac patients: a meta-analysis. J Cardiopulm Rehabil Prev. 2011 May–Jun;31(3):146–56. doi: 10.1097/HCR.0b013e3181fc0985. PMID: 21150634.21150634
43 Mazza M, Lotrionte M, Biondi-Zoccai G, . Selective serotonin reuptake inhibitors provide significant lower re-hospitalization rates in patients recovering from acute coronary syndromes: evidence from a meta-analysis. J Psychopharmacol. 2010 Dec;24(12):1785–92. doi: 10.1177/0269881109348176. PMID: 19965939.19965939
44 Thombs BD, de Jonge P, Coyne JC, . Depression screening and patient outcomes in cardiovascular care: a systematic review. JAMA. 2008 Nov 12;300(18):2161–71. doi: 10.1001/jama.2008.667. PMID: 19001627.19001627
45 Thombs BD, Magyar-Russell G, Bass EB, . Performance characteristics of depression screening instruments in survivors of acute myocardial infarction: review of the evidence. Psychosomatics. 2007 May–Jun;48(3):185–94. doi: 10.1176/appi.psy.48.3.185. PMID: 17478586.17478586
46 Tully PJ, Baumeister H. Collaborative care for comorbid depression and coronary heart disease: A systematic review and meta-analysis of randomised controlled trials. BMJ Open. 2015;5(12).
47 Baumeister H, Hutter N, Bengel J. Psychological and pharmacological interventions for depression in patients with coronary artery disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2011.
48 Archer J, Bower P, Gilbody S, . Collaborative care for depression and anxiety problems. Cochrane Database Syst Rev. 2012;10:Cd006525. doi: 10.1002/14651858.CD006525.pub2. PMID: 23076925.23076925
49 Dechartres A, Trinquart L, Boutron I, . Influence of trial sample size on treatment effect estimates: meta-epidemiological study. BMJ. 2013;346:f2304. doi: 10.1136/bmj.f2304. PMID: 23616031.23616031
50 Dechartres A, Altman DG, Trinquart L, . Association between analytic strategy and estimates of treatment outcomes in meta-analyses. JAMA. 2014 Aug 13;312(6):623–30. doi: 10.1001/jama.2014.8166. PMID: 25117131.25117131
51 Higgins JP, Altman DG, Gotzsche PC, . The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. doi: 10.1136/bmj.d5928. PMID: 22008217.22008217
52 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
53 Berkman ND, Lohr KN, Ansari M, . AHRQ Methods for Effective Health Care Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2008.
54 Schunemann HJ, Oxman AD, Brozek J, . Grading quality of evidence and strength of recommendations for diagnostic tests and strategies. BMJ. 2008 May 17;336(7653):1106–10. doi: 10.1136/bmj.39500.677199.AE. PMID: 18483053.18483053
55 Atkins D, Chang S, Gartlehner G, . AHRQ Methods for Effective Health Care. Assessing the Applicability of Studies When Comparing Medical Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2008.
56 McGuire AW, Eastwood JA, Macabasco-O’Connell A, . Depression screening: utility of the patient health questionnaire in patients with acute coronary syndrome. Am J Crit Care. 2013 Jan;22(1):12–9. doi: 10.4037/ajcc2013899. PMID: 23283084.23283084
57 Frasure-Smith N, Lesperance F. Depression and anxiety as predictors of 2-year cardiac events in patients with stable coronary artery disease. Arch Gen Psychiatry. 2008 Jan;65(1):62–71. doi: 10.1001/archgenpsychiatry.2007.4. PMID: 18180430.18180430
58 Huffman JC, Smith FA, Blais MA, . Rapid screening for major depression in post-myocardial infarction patients: an investigation using Beck Depression Inventory II items. Heart. 2006 Nov;92(11):1656–60. doi: 10.1136/hrt.2005.087213. PMID: 16644855.16644855
59 Huffman JC, Doughty CT, Januzzi JL, . Screening for major depression in post-myocardial infarction patients: Operating characteristics of the Beck-Depression Inventory-II. Int J Psychiatry Med. 2010;40(2):187–97. doi: 10.2190/PM.40.2.e. PMID: 2010-18061-005.20848875
60 Low GD, Hubley AM. Screening for depression after cardiac events using the Beck Depression Inventory-II and the Geriatric Depression Scale. Social Indicators Research. 2007;82(3):527–48. doi: 10.1007/s11205-006-9049-3. PMID: 2008-08604-008.
61 Bambauer KZ, Locke SE, Aupont O, . Using the Hospital Anxiety and Depression Scale to screen for depression in cardiac patients. Gen Hosp Psychiatry. 2005;27(4):275–84. doi: 10.1016/j.genhosppsych.2005.03.002. PMID: 2005-08290-009.15993261
62 Bunevicius A, Staniute M, Brozaitiene J, . Diagnostic accuracy of self-rating scales for screening of depression in coronary artery disease patients. J Psychosom Res. 2012 Jan;72(1):22–5. doi: 10.1016/j.jpsychores.2011.10.006. PMID: 22200518.22200518
63 Bush DE, Ziegelstein RC, Tayback M, . Even minimal symptoms of depression increase mortality risk after acute myocardial infarction. Am J Cardiol. 2001 Aug 15;88(4):337–41. PMID: 11545750.11545750
64 Frasure-Smith N, Lesperance F, Talajic M. Depression following myocardial infarction. Impact on 6-month survival. JAMA. 1993 Oct 20;270(15):1819–25. PMID: 8411525.8411525
65 Schleifer SJ, Macari-Hinson MM, Coyle DA, . The nature and course of depression following myocardial infarction. Arch Intern Med. 1989 Aug;149(8):1785–9. PMID: 2788396.2788396
66 Strik JJ, Honig A, Maes M. Depression and myocardial infarction: relationship between heart and mind. Prog Neuropsychopharmacol Biol Psychiatry. 2001 May;25(4):879–92. PMID: 11383983.11383983
67 Melartin TK, Rytsala HJ, Leskela US, . Current comorbidity of psychiatric disorders among DSM-IV major depressive disorder patients in psychiatric care in the Vantaa Depression Study. J Clin Psychiatry. 2002 Feb;63(2):126–34. PMID: 11874213.11874213
68 Lewinsohn PM, Zeiss AM, Duncan EM. Probability of relapse after recovery from an episode of depression. J Abnorm Psychol. 1989 May;98(2):107–16. PMID: 2708651.2708651
69 Bachmann LM, Puhan MA, ter Riet G, . Sample sizes of studies on diagnostic accuracy: literature survey. BMJ. 2006 May 13;332(7550):1127–9. doi: 10.1136/bmj.38793.637789.2F. PMID: 16627488.16627488
70 Mitchell AJ, Yadegarfar M, Gill J, . Case finding and screening clinical utility of the Patient Health Questionnaire (PHQ-9 and PHQ-2) for depression in primary care: a diagnostic meta-analysis of 40 studies. BJPsych Open. 2016 Mar;2(2):127–38. doi: 10.1192/bjpo.bp.115.001685. PMID: 27703765.27703765
71 Pocklington C, Gilbody S, Manea L, . The diagnostic accuracy of brief versions of the Geriatric Depression Scale: a systematic review and meta-analysis. Int J Geriatr Psychiatry. 2016 Aug;31(8):837–57. doi: 10.1002/gps.4407. PMID: 26890937.26890937
72 Wang YP, Gorenstein C. Psychometric properties of the Beck Depression Inventory-II: a comprehensive review. Rev Bras Psiquiatr. 2013 Oct–Dec;35(4):416–31. doi: 10.1590/1516-4446-2012-1048. PMID: 24402217.24402217
73 Mitchell AJ, Bird V, Rizzo M, . Diagnostic validity and added value of the Geriatric Depression Scale for depression in primary care: a meta-analysis of GDS30 and GDS15. J Affect Disord. 2010 Sep;125(1–3):10–7. doi: 10.1016/j.jad.2009.08.019. PMID: 19800132.19800132
74 Mitchell AJ, Meader N, Symonds P. Diagnostic validity of the Hospital Anxiety and Depression Scale (HADS) in cancer and palliative settings: a meta-analysis. J Affect Disord. 2010 Nov;126(3):335–48. doi: 10.1016/j.jad.2010.01.067. PMID: 20207007.20207007
75 Moriarty AS, Gilbody S, McMillan D, . Screening and case finding for major depressive disorder using the Patient Health Questionnaire (PHQ-9): a meta-analysis. Gen Hosp Psychiatry. 2015 Nov–Dec;37(6):567–76. doi: 10.1016/j.genhosppsych.2015.06.012. PMID: 26195347.26195347
76 Bjelland I, Dahl AA, Haug TT, . The validity of the Hospital Anxiety and Depression Scale. An updated literature review. J Psychosom Res. 2002 Feb;52(2):69–77. PMID: 11832252.11832252
77 Thombs BD, Ziegelstein RC. Does depression screening improve depression outcomes in primary care? BMJ. 2014 Feb 04;348:g1253. doi: 10.1136/bmj.g1253. PMID: 24496211.24496211
78 Strik JJ, Honig A, Lousberg R, . Sensitivity and specificity of observer and self-report questionnaires in major and minor depression following myocardial infarction. Psychosomatics. 2001 Sep–Oct;42(5):423–8. doi: 10.1176/appi.psy.42.5.423. PMID: 11739910.11739910
79 Banankhah SK, Friedmann E, Thomas S. Effective treatment of depression improves post-myocardial infarction survival. World J Cardiol. 2015 Apr 26;7(4):215–23. doi: 10.4330/wjc.v7.i4.215. PMID: 25914790.25914790
80 Ye S, Shaffer JA, Rieckmann N, . Long-term outcomes of enhanced depression treatment in patients with acute coronary syndromes. Am J Med. 2014 Oct;127(10):1012–6. doi: 10.1016/j.amjmed.2014.05.004. PMID: 24835038.24835038
81 Roest AM, Carney RM, Freedland KE, . Changes in cognitive versus somatic symptoms of depression and event-free survival following acute myocardial infarction in the Enhancing Recovery In Coronary Heart Disease (ENRICHD) study. J Affect Disord. 2013 Jul;149(1–3):335–41. doi: 10.1016/j.jad.2013.02.008. PMID: 23489396.23489396
82 Davidson KW, Bigger JT, Burg MM, . Centralized, stepped, patient preference-based treatment for patients with post-acute coronary syndrome depression: CODIACS vanguard randomized controlled trial. JAMA Intern Med. 2013 Jun 10;173(11):997–1004. doi: 10.1001/jamainternmed.2013.915. PMID: 23471421.23471421
83 Kronish IM, Rieckmann N, Burg MM, . The effect of enhanced depression care on adherence to risk-reducing behaviors after acute coronary syndromes: findings from the COPES trial. Am Heart J. 2012 Oct;164(4):524–9. doi: 10.1016/j.ahj.2012.07.024. PMID: 23067910.23067910
84 Davidson KW, Rieckmann N, Clemow L, . Enhanced depression care for patients with acute coronary syndrome and persistent depressive symptoms: coronary psychosocial evaluation studies randomized controlled trial. Arch Intern Med. 2010 Apr 12;170(7):600–8. doi: 10.1001/archinternmed.2010.29. PMID: 20386003.20386003
85 Saab PG, Bang H, Williams RB, . The impact of cognitive behavioral group training on event-free survival in patients with myocardial infarction: the ENRICHD experience. J Psychosom Res. 2009 Jul;67(1):45–56. doi: 10.1016/j.jpsychores.2009.01.015. PMID: 19539818.19539818
86 Cowan MJ, Freedland KE, Burg MM, . Predictors of treatment response for depression and inadequate social support--the ENRICHD randomized clinical trial. Psychother Psychosom. 2008;77(1):27–37. doi: 10.1159/000110057. PMID: 18087205.18087205
87 van Melle JP, de Jonge P, Honig A, . Effects of antidepressant treatment following myocardial infarction. Br J Psychiatry. 2007 Jun;190:460–6. doi: 10.1192/bjp.bp.106.028647. PMID: 17541103.17541103
88 Mendes de Leon CF, Czajkowski SM, Freedland KE, . The effect of a psychosocial intervention and quality of life after acute myocardial infarction: the Enhancing Recovery in Coronary Heart Disease (ENRICHD) clinical trial. J Cardiopulm Rehabil. 2006 Jan–Feb;26(1):9–13; quiz 4–5. PMID: 16617220.16617220
89 Schneiderman N, Saab PG, Catellier DJ, . Psychosocial treatment within sex by ethnicity subgroups in the Enhancing Recovery in Coronary Heart Disease clinical trial. Psychosom Med. 2004 Jul–Aug;66(4):475–83. doi: 10.1097/01.psy.0000133217.96180.e8. PMID: 15272091.15272091
90 Carney RM, Blumenthal JA, Freedland KE, . Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. 2004 Jul–Aug;66(4):466–74. doi: 10.1097/01.psy.0000133362.75075.a6. PMID: 15272090.15272090
91 Berkman LF, Blumenthal J, Burg M, . Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. 2003 Jun 18;289(23):3106–16. doi: 10.1001/jama.289.23.3106. PMID: 12813116.12813116
92 Zuidersma M, Conradi HJ, van Melle JP, . Depression treatment after myocardial infarction and long-term risk of subsequent cardiovascular events and mortality: a randomized controlled trial. J Psychosom Res. 2013 Jan;74(1):25–30. doi: 10.1016/j.jpsychores.2012.08.015. PMID: 23272985.23272985
93 Unutzer J, Katon W, Callahan CM, . Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. 2002 Dec 11;288(22):2836–45. PMID: 12472325.12472325
94 Button KS, Kounali D, Thomas L, . Minimal clinically important difference on the Beck Depression Inventory--II according to the patient’s perspective. Psychol Med. 2015 Nov;45(15):3269–79. doi: 10.1017/S0033291715001270. PMID: 26165748.26165748
95 Masson SC, Tejani AM. Minimum clinically important differences identified for commonly used depression rating scales. J Clin Epidemiol. 2013 Jul;66(7):805–7. doi: 10.1016/j.jclinepi.2013.01.010. PMID: 23618794.23618794
96 Ziegelstein RC, Thombs BD, Coyne JC, . Routine screening for depression in patients with coronary heart disease never mind. J Am Coll Cardiol. 2009 Sep 01;54(10):886–90. doi: 10.1016/j.jacc.2009.01.082. PMID: 19712796.19712796
97 Blumenthal JA, O’Connor C. No laughing matter. J Am Coll Cardiol. 2010 Feb 23;55(8):836; author reply -7. doi: 10.1016/j.jacc.2009.09.048. PMID: 20170826.20170826
98 Katon WJ, Lin EH, Von Korff M, . Collaborative care for patients with depression and chronic illnesses. N Engl J Med. 2010 Dec 30;363(27):2611–20. doi: 10.1056/NEJMoa1003955. PMID: 21190455.21190455
99 Crowley RA, Kirschner N. The integration of care for mental health, substance abuse, and other behavioral health conditions into primary care: executive summary of an American College of Physicians position paper. Ann Intern Med. 2015 Aug 18;163(4):298–9. doi: 10.7326/m15-0510. PMID: 26121401.26121401
100 Gilbody S, Sheldon T, House A. Screening and case-finding instruments for depression: a meta-analysis. CMAJ. 2008 Apr 8;178(8):997–1003. doi: 10.1503/cmaj.070281. PMID: 18390942.18390942
101 Carney RM, Steinmeyer BC, Freedland KE, . Baseline blood levels of omega-3 and depression remission: a secondary analysis of data from a placebo-controlled trial of omega-3 supplements. J Clin Psychiatry. 2016 Feb;77(2):e138–43. doi: 10.4088/JCP.14m09660. PMID: 26930527.26930527
102 Arana GW, Rosenbaum JF. Antidepressant drugs. In: Handbook of Psychiatric Drug Therapy, 4th ed, Lippincott Williams & Wilkins, Philadelphia 2000. p.53.
103 Fournier JC, DeRubeis RJ, Hollon SD, . Antidepressant drug effects and depression severity: a patient-level meta-analysis. JAMA. 2010 Jan 06;303(1):47–53. doi: 10.1001/jama.2009.1943. PMID: 20051569.20051569
104 Press MJ, Howe R, Schoenbaum M, . Medicare Payment for Behavioral Health Integration. N Engl J Med. 2017 Feb 02;376(5):405–7. doi: 10.1056/NEJMp1614134. PMID: 27973984.27973984
105 . Screening for depression in adults: U.S. preventive services task force recommendation statement. Ann Intern Med. 2009 Dec 01;151(11):784–92. doi: 10.7326/0003-4819-151-11-200912010-00006. PMID: 19949144.19949144
106 O’Connor EA, Whitlock EP, Beil TL, . Screening for depression in adult patients in primary care settings: a systematic evidence review. Ann Intern Med. 2009 Dec 01;151(11):793–803. doi: 10.7326/0003-4819-151-11-200912010-00007. PMID: 19949145.19949145
107 Blumenthal JA, Babyak MA, O’Connor C, . Effects of exercise training on depressive symptoms in patients with chronic heart failure: the HF-ACTION randomized trial. JAMA. 2012 Aug 01;308(5):465–74. doi: 10.1001/jama.2012.8720. PMID: 22851113.22851113
108 Cooney GM, Dwan K, Greig CA, . Exercise for depression. Cochrane Database Syst Rev. 2013 Sep 12(9):Cd004366. doi: 10.1002/14651858.CD004366.pub6. PMID: 24026850.24026850
109 Davidson K. ClinincalTrials.gov study listing: Comparison of Depression Identification After Acute Coronary Syndrome: Quality of Life and Cost Outcomes (CODIACSQoL). Available at: https://clinicaltrials.gov/ct2/show/NCT01993017. Accessed June 14, 2017.
110 Blumenthal JA, Smith PJ, Hoffman BM. Is Exercise a Viable Treatment for Depression? ACSMs Health Fit J. 2012 Jul;16(4):14–21. doi: 10.1249/01.FIT.0000416000.09526.eb. PMID: 23750100.23750100
111 Hallahan B, Ryan T, Hibbeln JR, . Efficacy of omega-3 highly unsaturated fatty acids in the treatment of depression. Br J Psychiatry. 2016 Sep;209(3):192–201. doi: 10.1192/bjp.bp.114.160242. PMID: 27103682.27103682
112 Sarris J, Murphy J, Mischoulon D, . Adjunctive Nutraceuticals for Depression: A Systematic Review and Meta-Analyses. Am J Psychiatry. 2016 Jun 01;173(6):575–87. doi: 10.1176/appi.ajp.2016.15091228. PMID: 27113121.27113121
113 Myers E, Sanders GD, Ravi D, . AHRQ Methods for Effective Health Care. Evaluating the Potential Use of Modeling and Value-of-Information Analysis for Future Research Prioritization Within the Evidence-Based Practice Center Program. Rockville (MD): Agency for Healthcare Research and Quality (US); 2011.