# Methods

We followed the methods for this comparative effectiveness review provided by the Agency for Healthcare Research and Quality (AHRQ)’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the Methods Guide) for the Evidence-based Practice Center (EPC) program.^31^ Certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.^32^ All methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

During topic refinement, we generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). Initially a panel of key informants representing medical professionals and researchers with expertise in areas of cardiology, cardiovascular and pulmonary rehabilitation, psychiatry, psychology, and family medicine; and patients/caregivers gave input on the KQs to be examined; these KQs were posted on AHRQ’s Effective Health Care (EHC) Web site for public comment from May 26, 2016 to June 15, 2016, and were revised to refine the screening tools, interventions, and outcomes of interest. These revisions were made prior to seeing the results of any studies. We then drafted a protocol for the systematic review and recruited a panel of technical experts (TEP) to provide high-level content and methodological expertise and finalized the review protocol. The TEP included medical professionals, researchers, and topic experts from other Health and Human Services agencies. The finalized protocol is posted on the EHC Web site (www.effectivehealthcare.ahrq.gov). The PROSPERO registration is CRD42016047032.

## Literature Search Strategy

### Search Strategy

To identify relevant published literature, we searched MEDLINE^®^ (via PubMed), Embase^®^, PsycINFO^®^, CINAHL^®^, and the Cochrane Database of Systematic Reviews (CDSR), limiting the search to articles published from January 1, 2003, to August 15, 2017. These databases were selected based on (1) expert opinion that they would identify most of the relevant literature on this topic and (2) the approaches of prior related systematic reviews.^1^ We believe that the evidence published from 2003 both represents the current standard of care for the population of interest in this review and allows this report to build on the previous AHRQ systematic review^1^ published in 2005 (which had an electronic search date through March 2004). The overlap in search dates follows EPC methods guidance.^31^

We used a combination of medical subject headings and title and abstract keywords, focusing on terms to describe the relevant population and interventions of interest. Exact search strings used for each KQ are in Appendix B. Where possible, we used existing validated search filters. An experienced search librarian guided all searches. We supplemented the electronic searches with a manual search of citations from a set of key primary and review articles.^33–47^ The reference list for identified pivotal articles was hand-searched and cross-referenced against our database, and additional relevant manuscripts were retrieved. All citations were imported into an electronic bibliographical database (EndNote^®^ Version X7; Thomson Reuters, Philadelphia, PA).

To identify relevant gray literature, the EPC Scientific Resource Center notified stakeholders that the EPC was interested in receiving information that the stakeholders would consider relevant to the KQs. We also searched ClinicalTrials.gov for two purposes: (1) to identify relevant articles from completed studies that may not have appeared in our other search strategies and (2) as one mechanism to ascertain publication bias in recent studies. For the latter goal, we sought to identify completed but unpublished studies that could impact the findings of the review. Search terms used for ClinicalTrials.gov are provided in Appendix B. We also explored the possibility of publication bias specifically in our quantitative synthesis of the included literature through meta-analysis techniques such as a funnel plot when appropriate.

### Inclusion and Exclusion Criteria

We specified our inclusion and exclusion criteria based on the PICOTS identified for each question. Table 1 specifies inclusion and exclusion criteria. In brief, eligibility criteria were designed to include patients with clinically important depressive symptoms, occurring within 3 months post ACS. The 3-month post-ACS criterion was chosen for consistency with the original report, and to identify a post-ACS population that could be distinguished from patients with chronic coronary heart disease. Studies evaluating screening instruments had to compare an eligible questionnaire to a criterion standard diagnosis. Studies evaluating intervention effects had to evaluate any FDA-approved antidepressant, an inclusive list of psychotherapies and other treatments, or an enhanced care model.

Table 1 Inclusion and exclusion criteria

PICOTS Element | Inclusion Criteria | Exclusion Criteria
Populations | KQ 1: Adults who have acute coronary syndrome (ACS) [which includes both unstable angina and myocardial infarction (MI)] and are within 3 months of an identifying ACS event KQ 2: Adults who received a criterion-based diagnosis of depression or had clinically important depressive symptoms using a validated depression scale, and are within 3 months of an acute ACS event Subgroups of interest:; - Age (KQ 1, KQ 2) older adults (≥65 years) versus adults younger than 65 years of age; - Race/ethnicity (KQ 1, KQ 2); - Sex (KQ 1, KQ 2); - Inpatient vs outpatient (KQ 1) | KQs 1 and 2: Individuals younger than 18 years of age. Studies including mixed samples (e.g., both adults and patients under 18, or a mixture of patients within 3 months of an ACS event and those who are more than 3 months post-event) were excluded unless data for the target population were reported separately. KQ 2: Depression diagnosis made by unstructured clinical diagnosis, chart diagnosis, or based on administrative codes (rather than DSM) or prescription for an antidepressant
Interventions | KQ 1:; - Screening tools for depression, limited to:; ○ Beck Depression Inventory (BDI) (multiple versions); ○ Center for Epidemiologic Studies-Depression (CES-D20 and CES-D10); ○ Distress Questionnaire 5; ○ Duke Anxiety and Depression Scale; ○ Geriatric Depression Scale (GDS-15) [2 versions, long and short]; ○ Hospital Anxiety and Depression Scale (HADS and HADS-D); ○ Diagnostic Inventory for Depression (DID); ○ Kessler Psychological Distress Scale (K10 and K6); ○ Patient Health Questionnaire (PHQ-2, 8, 9, 10); ○ Primary care rapid evaluation of mental disorders (PRIME-MD, including Whooley questions); ○ PROMIS^®^ (Patient-Reported Outcomes Measurement Information System); ○ Quick Inventory of Depressive Symptomatology; ○ Symptom Checklist 20 and Hopkins Symptom Checklist; ○ WHO-5 (World Health Organization-5); ○ Zung Self-Rating Depression Scale; - Screening strategies that differ by setting (i.e, inpatient vs outpatient, general medicine vs cardiology) or timing (i.e., duration post-ACS event); KQ 2 (considered singly or in combination):; - Medical Therapy; ○ Antidepressant medications (SSRI, SNRI, etc.) limited to second-generation medications that have been FDA-approved for treatment of major depressive disorder:; ■ Bupropion; ■ Citalopram; ■ Desvenlafaxine; ■ Duloxetine; ■ Fluoxetine; ■ Escitalopram; ■ Levomilnacipran; ■ Mirtazapine; ■ Nefazodone; ■ Paroxetine; ■ Sertraline; ■ Trazodone; ■ Venlafaxine; ■ Vilazodone; ■ Vortioxetine; ○ Atypical antipsychotics – limited to those that are FDA-approved for treatment of major depressive disorder:; ■ Aripiprazole; ■ Olanzapine; ■ Quetiapine; ○ Tricyclic antidepressants – limited to those that are FDA-approved for treatment of major depressive disorder:; ■ Amitryptiline; ■ Amoxapine; ■ Desipramine; ■ Doxepin; ■ Imipramine; ■ Nortryptiline; ■ Protryptiline; ■ Trimipramine; - Psychotherapy; ○ Cognitive behavioral therapy, limited to: cognitive behavioral therapy (CBT), cognitive therapy, behavioral therapy, cognitive behavioral analysis system of psychotherapy, and behavioral activation; ○ Problem solving therapy; ○ Interpersonal psychotherapy; ○ Short-term psychodynamic therapy; ○ “Third wave” cognitive behavioral psychotherapies, limited to: acceptance and commitment therapy, dialectical behavior therapy, mindfulness, mindfulness-based cognitive therapy (MBCT), and functional analytic psychotherapy; - Other Treatments; ○ Structured aerobic exercise: Structured exercise is defined as regular physical activity done with the intention of improving or maintaining physical fitness or health, or performed as part of a class or with support from a health professional.; ○ St John’s Wort; ○ Fish oil/omega-3 fatty acids; ○ S-Adenosylmethionine; ○ Cardiac rehabilitation which typically includes supervised exercise training in conjunction with other secondary prevention interventions (e.g., psychosocial support, stress management, nutrition counseling, education on medication adherence).; ○ Education/psychoeducation; ○ Stress management: mindfulness meditation, progressive muscle relaxation, qigong meditation, spiritual medication, guided imagery-based approaches, paced respiration, Roll breathing, 4-7-8 breath technique; ○ Psychosocial support: interventions to help a person cope with stress that do not involve formal therapy; ○ Transcranial magnetic stimulation; ○ Electroconvulsive therapy; - Enhanced Care Delivery; ○ Collaborative care in primary care or cardiology settings (Note that such care integrates psychiatric treatment into other settings. “Patients are treated by a team that usually includes a primary care clinician, a case manager who provides support and outreach to patients, and a mental health specialist (e.g., psychiatrist) who provides consultation and supervision. Other elements include a structured treatment plan that involves pharmacotherapy and/or other interventions (e.g., patient education or cognitive-behavioral therapy), scheduled followup visits, communication amongst the members of the treatment team, and measurement-based care.”^48^) | KQ 2: Combination interventions that include an ineligible intervention
Comparators | KQ 1: Validated criterion standard (e.g., DSM or ICD criteria) administered by a trained interviewer KQ 2: Active comparator from listed interventions; usual care | KQ 2: Same treatment comparisons that vary by dose; combination comparators that include an ineligible intervention
Outcomes | KQ 1:; - Diagnostic accuracy, as measured by:; ○ Sensitivity; ○ Specificity; ○ Negative predictive value (NPV); ○ Positive predictive value (PPV); ○ Likelihood ratios; ○ Receiver operating characteristic (ROC) curves; KQ 2:; - Clinical outcomes; ○ Total mortality; ○ Depression-related outcomes; ■ Response or remission of depressive symptoms using validated continuous or categorical measures; ○ Cardiac-related outcomes; ■ Cardiac mortality; ■ Repeat ACS event (repeat MI or unstable angina); ■ Resuscitated arrest; ■ Stroke; ■ Arrhythmias; ■ Revascularization; - Quality of life (QOL); - Cost-effectiveness; - Utilization of health care services; ○ Cardiac medication adherence; ○ Readmission rates due to cardiac and non-cardiac reasons; ○ Emergency room visits: all visits, cardiac-related, and psychiatric-related; - Discontinuation of depression intervention due to adverse effects; - Adverse effects of treatment (excluding clinical outcomes listed above); ○ Weight gain; ○ Gastrointestinal bleeding; ○ Arrhythmias; ○ Suicidal ideation, behaviors or attempts
Timing | KQ 1: Within 3 months of an identifying ACS event KQ 2: At least 6 weeks of followup
Settings | - Primary, specialty, and inpatient settings; - Studies conducted in countries with similar cardiac care and similar concept of depressive disorders to that of the United States: North America, European Union and the UK, Australia, New Zealand
Study design | - Original peer-reviewed data; - KQ 1: Observational studies, sample size ≥50 subjects; - KQ 2: Randomized controlled trials (RCTs), sample size ≥20 subjects | Editorials, nonsystematic reviews, systematic reviews, meta analyses, letters, case series, case reports, abstract-only or poster publications, articles that have been retracted or withdrawn Because studies with fewer than 20 subjects are often pilot studies or studies of lower quality,^49, 50^ we have excluded them from our review. For observational studies, we require at least 50 subjects.
Publications | - English-language only; - Published on or after January 1, 2003 | Non-English language articles^a^

a Non-English language articles were excluded due to: (1) the high volume of literature available in English language publications, (2) the focus of our review on applicability to populations in the United States, and (3) the scope of our KQs.

Abbreviations: ACS=acute coronary syndrome; CBT=cognitive behavioral therapy; DSM=Diagnostic and Statistical Manual of Mental Disorders; ICD=International Classification of Diseases; FDA=U.S. Food and Drug Administration; KQ=Key Question; MBCT=mindfulness-based cognitive therapy; MI=myocardial infarction; NPV=negative predictive value; PICOTS=Populations, Interventions, Comparators, Outcomes, Timing, Settings; PPV=positive predictive value; QOL=quality of life; ROC=receiver operating characteristic; RCTs=randomized controlled trials; SNRI=serotonin–norepinephrine reuptake inhibitor; SSRI=selective serotonin reuptake inhibitors

### Study Selection

For citations retrieved from MEDLINE, Embase, PsycINFO, CINAHL, and the CDSR, two reviewers used the prespecified inclusion/exclusion criteria to review titles and abstracts for potential relevance to the research questions. Articles included by either reviewer underwent full-text screening. At the full-text screening stage, two independent reviewers were required to agree on a final inclusion/exclusion decision. In recording reasons for exclusion, articles were assessed against a hierarchical list of exclusion reason possibilities; these options are presented in order in the literature flow diagram (Figure 2) and Appendix E. Screeners were instructed to select the first applicable exclusion reason encountered in that order. Disagreements in inclusion/exclusion or exclusion reason decisions were resolved by a third expert member of the team. Articles meeting eligibility criteria were included for data abstraction. At random intervals during screening, quality checks by senior team members were made to ensure that screening and abstraction were consistent with inclusion/exclusion criteria and abstraction guidelines. All results were tracked using the DistillerSR data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada).

Appendix D provides a list of all articles included for data abstraction. Appendix E provides a list of articles excluded at the full-text screening stage, with reasons for exclusion.

### Data Extraction

The research team created abstraction forms that were programmed into DistillerSR software or excel to collect the data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate, final, and adverse events outcomes). Particular attention was given to describing the details of the screening approach (e.g., instrument version, administration mode), details of the treatment (e.g., pharmacotherapy dosing, methods of behavioral interventions, co-interventions), patient characteristics (e.g., depressive disorder, age) that may be related to outcomes. In addition, we described comparators carefully, as treatment standards may have changed during the period covered by the review. The safety outcomes were framed to help identify adverse events, including those from drug therapies and those resulting from misdiagnosis and labeling. Data necessary for assessing quality and applicability, as described in the Methods Guide,^31^ were also abstracted. A list of data abstraction elements is provided in Appendix C.

All data abstraction form templates were pilot-tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. Forms were revised as necessary before full abstraction of all included articles.

Based on clinical and methodological expertise, a pair of researchers abstracted data from each of the eligible articles, with one researcher abstracting the data and the second over-reading the article and the accompanying abstraction to check for accuracy and completeness. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion if consensus was not reached. To avoid duplication of patient cohorts, we linked related studies.

Final abstracted data will be uploaded to AHRQ’s Systematic Review Data Repository (https://srdr.ahrq.gov/).

## Quality Assessment of Individual Studies

We assessed the methodological quality, or risk of bias, for each individual study based on the Cochrane Risk of Bias^51^ tool for randomized studies and the Quality Assessment of Diagnostic Accuracy Studies-2 (QUADAS-2)^52^ for observational studies. Observational studies were rated on each individual quality criterion without a summary rating. For each randomized controlled trial (RCT), one investigator assessed methodological quality, which was then reviewed by a second investigator; disagreements were resolved by consensus or by a third investigator if agreement was not reached. Individual components of the Cochrane tool were rated as low, high, or unclear risk of bias. We then rated each RCT as being of good, fair, or poor quality based on its adherence to well-accepted standard methodologies following the definitions in the AHRQ Methods Guide. The rating was outcome-specific such that a given study that analyzed its primary outcome well but did an incomplete analysis of a secondary outcome could be assigned a different quality grade for each of the two outcomes. We applied this outcome-specific quality assessment to groups of outcomes that have lower risk of detection bias (e.g., mortality) and those at higher risk of detection bias (e.g., depression symptoms).

Studies of different designs were evaluated within the context of their respective designs. RCT quality was summarized as good, fair, or poor. Table 2 defines these quality ratings, which are presented in the Results section, Appendix G, and the strength of evidence tables in the Discussion section of the report. Observational studies were graded using QUADAS-2 methodology with graphics showing judgments for each quality item.

Table 2 Definition of quality assessment ratings for randomized controlled trials

Rating | Definition
Good (low risk of bias) | These studies had the least bias, and the results were considered valid. These studies adhered to the commonly held concepts of high quality, including the following: a clear description of the population, setting, approaches, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytical methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
Fair (unclear risk of bias) | These studies were susceptible to some bias, but not enough to invalidate the results. They did not meet all the criteria required for a rating of good quality because they had some deficiencies, but no flaw was likely to cause major bias. The study may have been missing information, making it difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies had significant flaws that might have invalidated the results. They had serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

## Data Synthesis

We began by summarizing key features of the included studies for each KQ. To the degree that data were available, we abstracted information on study design; patient characteristics; clinical settings; interventions; and intermediate, final, and adverse event outcomes. We ordered our findings by treatment or diagnostic comparison and then within these comparisons by outcome with long-term final outcomes emphasized.

We reviewed and highlighted studies using a hierarchy-of-evidence approach. The best evidence available was the focus of our synthesis for each KQ. If high-quality evidence was not available, we described any lower quality evidence we were able to identify, but we underscored the issues that made it lower quality and the uncertainties in our findings. We assessed and stated whether the inclusion of lower quality studies would change any of our conclusions and performed sensitivity analyses excluding this evidence where appropriate.

We then determined the feasibility of completing quantitative syntheses (i.e., meta-analyses). Feasibility was dependent on the volume of relevant literature (we required 3 appropriate studies to consider meta-analysis), conceptual homogeneity of the studies, completeness of the reporting of results, and the power of the proposed meta-analysis. When a meta-analysis was appropriate, we used random-effects models (DerSimonian-Laird estimator with Knapp-Hartung standard error adjustment) to synthesize the available evidence quantitatively. For KQ 1, proportions were summarized on the logit (log odds) scale and then converted back to a proportion. Individual study sensitivities and specificities were calculated with exact 95 percent confidence intervals. Sensitivities and specificities were summarized separately as proportions because a joint model, which would have summarized these together, did not converge.

For KQ 2, we anticipated that intervention effects may be heterogeneous. We hypothesized that the methodological quality of individual studies, study type, the characteristics of the comparator, and patients’ underlying clinical presentation were associated with the intervention effects. We planned subgroup analyses and/or meta-regression analyses to examine these hypotheses, but quantitative analyses were not feasible because of the small number of studies with diverse comparisons. Where possible we calculated effect sizes using standardized mean differences.

## Strength of the Body of Evidence

We selected a specific set of comparisons and outcomes for strength of evidence grading. The aim was to identify and grade those outcomes that are critical for decisionmaking. We graded the strength of evidence for each selected outcome separately.

We assessed the strength of evidence using the approach described in AHRQ’s Methods Guide.^31, 53^ We graded the strength of evidence for each outcome assessed; thus, the strength of evidence for two separate outcomes in a given study may be graded differently. These grades are presented in the strength of evidence tables in the Discussion section of the report. In brief, the approach requires assessment of five domains: study limitations (previously named risk of bias), consistency, directness, precision, and reporting bias, which includes publication bias, outcome reporting, and analysis reporting bias. For intervention trials, these domains affect the confidence in treatment effects. For diagnostic test studies, these factors affect the confidence in estimates of test accuracy and effects on patient management.^54^ These domains were considered qualitatively, and a summary rating of high, moderate, or low strength of evidence was assigned for each outcome after independent assessment and then discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make, for example, when no evidence is available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of “insufficient” was assigned. Table 3 defines the four-level grading scale.

Table 3 Definition of strength of evidence grades

Rating | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Applicability

We assessed applicability across our KQs using the method described in AHRQ’s Methods Guide.^31, 55^ In brief, this method uses the PICOTS format as a way to organize information relevant to applicability. The most important issue with respect to applicability is whether the outcomes are different across studies that recruit different populations (e.g., age groups, depression severity, psychiatric and medical comorbidities) or use different methods to implement the interventions of interest; that is, important characteristics are those that affect baseline (control group) rates of events, intervention group rates of events, or both. We used a checklist to guide assessment of the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison with the target population, characteristics of the intervention used in comparison with care models currently in use, and clinical relevance and timing of the outcome measures (Appendix C). We summarized issues of applicability qualitatively.

## Peer Review and Public Commentary

Experts in the fields of mental health, cardiology, primary care, and systematic review methodology were invited to provide external peer review of the draft report. AHRQ, an associate editor, and members of the TEP were also given the opportunity to provide comments. In addition, the draft report was posted on the AHRQ EHC Web site for public comment from April 27, 2017, to May 25, 2017. We have addressed all reviewer comments, revising the text as appropriate, and have documented our responses in a disposition of comments report that will be made available 3 months after the Agency posts the final systematic review on the EHC Web site. A list of peer reviewers submitting comments on the draft report is provided in the front matter of this report.