# Introduction

## Background

In 2005, the Agency for Healthcare Research and Quality (AHRQ) published a systematic review on depression in patients following myocardial infarction (MI).^1^ That review addressed six Key Questions spanning the prevalence of depression during initial hospitalization and following discharge, the association of post-MI depression with outcomes of interest, the comparison of outcomes of post-MI patients with and without depression, the performance characteristics of instruments used for screening for depression post MI, and the use of cardiac treatments in this patient population. This current review builds on that original review but focuses on the questions and populations currently of greatest clinical uncertainty. Specifically, it evaluates (1) the diagnostic accuracy of selected depression screening instruments and strategies versus a validated criterion standard in adult patients within 3 months of an acute coronary syndrome (ACS) event, and (2) the comparative safety and effectiveness of a broad range of pharmacologic and nonpharmacologic treatments for depression in adult patients who have received a criterion-based diagnosis of depression or had clinically important depressive symptoms using a validated depression scale, and who are within 3 months of an ACS event.

### Condition: Post–Acute Coronary Syndrome Depression

Heart disease is the leading cause of death worldwide.^2^ In the United States, where it is the leading cause of death for both men and women, heart disease accounts for more than 600,000 deaths annually, or 23.5 percent of deaths from all causes.^3^ Over 25 million adults in the United States are currently estimated to be living with a diagnosis of heart disease,^4^ and over 1 million Americans are estimated to be hospitalized for an acute coronary syndrome (ACS) each year.^5^

For the purpose of this review, ACS refers to clinical symptoms compatible with acute myocardial ischemia and includes unstable angina, non-ST-segment elevation myocardial infarction (NSTEMI), and ST-segment elevation myocardial infarction (STEMI). Patients who are diagnosed with ACS are at risk for a range of negative health outcomes. Among these, post-ACS patients may be at increased risk for mental health problems—including major depressive disorder (MDD) and elevated symptoms of depression.^6^ Major depressive disorders are characterized by persistent depressed mood or anhedonia, along with other associated symptoms such as sleep disturbance or decreased energy, feelings of worthlessness and functional impairment for at least 2 weeks. In the general population, lifetime prevalence of major depressive disorder is approximately 17 percent,^7^ but studies have found that as many as 20 percent of post-ACS patients have MDD and 65 percent of post-MI patients experience elevated symptoms of depression.^8–10^ Major depressive disorder, persistent depressive disorder (Diagnostic and Statistical Manual of Mental Disorders [DSM]-IV dysthymia), and subsyndromal depression are highly prevalent in general medical populations (2–16% within the United States)^11–15^ and are estimated as the second largest cause of loss in disability-adjusted life years.^16^ Depressive disorders are associated with chronic medical illness, including cardiovascular disease, and worse general medical outcomes. Patients with depression post-ACS have significantly increased risk of death.^17, 18^

Despite the high prevalence of depression, the association with cardiovascular disease, and the impact of depression on quality of life (QOL), there is considerable uncertainty about whether and how to screen patients for depression post-ACS.^19^ Guidelines for screening for depression in primary care settings vary. The 2016 guidelines from the U.S. Preventive Services Task Force (USPSTF) recommend that depression screening for the general population in primary care be “implemented with adequate systems in place to ensure accurate diagnosis, effective treatment, and appropriate follow up.”^20^ However, other guidelines recommend targeted screening for patients at increased risk of depression^21^ or against routine screening.^22^ Individuals post-ACS are at higher risk for depression, and some professional societies recommend routine screening during and after the post-MI hospitalization, but these guidelines are controversial.^23, 24^ It is unclear how well standard instruments for detecting depression perform in this medically ill group and whether this group would benefit from targeted screening.

It is also unclear whether post-ACS patients with depression respond any differently than people in the general population with depression to commonly used, empirically validated treatments for depression. Such treatments include pharmacotherapy and psychotherapy, with second-generation antidepressants and cognitive behavioral therapy (CBT) being among the most widely supported, evidence-based depression treatment approaches. Both pharmacotherapy and psychotherapy have been shown to be effective,^17^ although it is unclear whether combination therapy is superior to pharmacotherapy or psychotherapy alone. It is possible, though not clearly established, that some of these treatments for depression may function differently in post-MI patients.^25^ For instance, behavioral activation, a core component of many CBT-based approaches, might encourage the adoption of new behavioral repertoires that not only improve mood but also medical outcomes.^26^ Other therapies also have been demonstrated to have beneficial effects for emotional health^27^ and cardiovascular health.^28^ In particular, aerobic exercise has been shown to improve survival in post-ACS patients and also may reduce depression.^29, 30^ Alternatively, it may be that certain depression treatments that are usually effective in the general population are less so among post-ACS patients, or carry certain risks that might be of particular concern in this population.^25^

### Screening Strategies

A number of screening tools for depression have been developed. This review sought to evaluate tools (described in the Results chapter), which were selected because they are feasible to use and have been validated in general populations. We also evaluated screening strategies that differ by setting (e.g., inpatient vs. outpatient, general medicine vs. cardiology) or timing (e.g., duration post-ACS). These tools and strategies were compared against the gold standard of a validated criterion standard (e.g., DSM or International Classification of Diseases [ICD] criteria) administered by a trained interviewer.

### Treatment Strategies

Pharmacologic treatments considered for patients with depression included second-generation antidepressants (e.g., selective serotonin reuptake inhibitor [SSRIs], serotonin-norepinephrine reuptake inhibitor [SNRIs]), atypical antipsychotics, and tricyclic antidepressants. For all three categories, the specific medications evaluated were limited to those that are Food and Drug Administration (FDA)-approved for treatment of MDD. Information on the FDA status and warnings for use the medications considered in this review are provided in Appendix A.

Nonpharmacologic treatments considered included various types of psychotherapy, aerobic exercise, selected dietary supplements, cardiac rehabilitation, education/psychoeducation, stress management, psychosocial support, transcranial magnetic stimulation, electroconvulsive therapy, and combinations of these approaches. Collaborative care, a method to improve care delivery which integrates psychiatric treatment into other clinical settings, also was evaluated. In such strategies, patients are treated by a team that usually includes a primary care clinician, a case manager who provides support and outreach to patients, and a mental health specialist (e.g., psychiatrist) who provides consultation and supervision. Other elements include a structured treatment plan that involves pharmacotherapy and/or other interventions (e.g., patient education or cognitive-behavioral therapy), scheduled followup visits, communication amongst the members of the treatment team, and measurement-based care.

## Scope and Key Questions

### Scope of Review

This review evaluates (1) the diagnostic accuracy of selected depression screening instruments and strategies versus a validated criterion standard in adult patients within 3 months of an ACS event, and (2) the comparative safety and effectiveness of a broad range of pharmacologic and nonpharmacologic treatments for depression in adult patients who have received a criterion-based diagnosis of depression or had clinically important depressive symptoms using a validated depression scale, and who are within 3 months of an ACS event. As noted above, we use ACS to include unstable angina, NSTEMI, and STEMI.

### Key Questions

The specific Key Questions (KQs) addressed in this review are listed below, and Figure 1 displays the analytic framework that guided our work.

KQ 1 What is the accuracy of depression screening instruments or screening strategies compared to a validated criterion standard in post-ACS patients?
KQ 2 What are the comparative safety and effectiveness of pharmacologic and nonpharmacologic depression treatments in post-ACS patients?

Figure 1 Analytic framework

Abbreviations: ACS=acute coronary syndrome; GI=gastrointestinal; KQ=Key Question; NPV=negative predictive value; PPV=positive predictive value; ROC=receiver operating characteristic

Figure 1 depicts the key questions (KQs) within the context of the populations, interventions, comparators, outcomes, timings, and settings (PICOTS) considered in this review. The figure illustrates how individuals who are post-acute coronary syndrome (ACS) may be screened and treated for depression, and how treatment is associated with a range of potential adverse effects and outcomes. Separate KQs address the accuracy of screening (KQ 1) and the effectiveness and risk of adverse events associated with pharmacologic and/or nonpharmacologic treatments (KQ 2). The patient population of interest for KQ1 is adults who have ACS [which includes both unstable angina and myocardial infarction (MI)] and are within 3 months of an identifying ACS event. The patient population of interest for KQ2 is adults who received a criterion-based diagnosis of depression or had clinically important depressive symptoms using a validated depression scale, and are within 3 months of an acute ACS event. Outcomes of interest for KQ1 are measures of diagnostic accuracy. Outcome types of interest for KQ2 include clinical outcomes, quality of life, cost-effectiveness, utilization of healthcare services, and discontinuation of depression interventions due to adverse effects. Further adverse effects of treatment considered include weight gain; gastrointestinal (GI) bleeding; arrhythmias; and suicidal ideation, behaviors, or attempts.

Figure 1 depicts the KQs within the context of the population, interventions, comparators, outcomes, timing, and settings (PICOTS) considered in this review. In general, the figure illustrates how individuals who are post-ACS may be screened and treated for depression, and how treatment is associated with a range of potential adverse effects and outcomes. Separate KQs address the accuracy of screening (KQ 1) and the effectiveness and risk of adverse events associated with pharmacologic and/or nonpharmacologic treatments (KQ 2).

It should be noted that the scope of the review does not explicitly address the linkage between the use of screening tools in KQ 1 and downstream clinical outcomes. This limitation in scope is addressed in the discussion of the findings and highlighted as an area for potential future research later in the report. Also, although ease of use and user burden are not listed within KQ 1 as specific outcomes of interest, we include a summary table of included screening tool characteristics (e.g., number of items, ease of use, availability) to aid in the comparison and interpretation of our findings.

## Organization of This Report

The remainder of the report details our methodology and presents the results of our literature synthesis, with summary tables and strength of evidence grading for major comparisons and outcomes. In the discussion section, we offer our conclusions, summarized findings, and other information that may be relevant to translating this work for clinical practice and future research.

Appendixes provide further details on our methods and the studies we assessed, as follows:

- Appendix A. FDA Status and Warnings for Drugs Included in This Review
- Appendix B. Exact Search Strings
- Appendix C. Data Abstraction Elements
- Appendix D. List of Included Studies
- Appendix E. List of Excluded Studies
- Appendix F. Key to Included Primary and Companion Articles
- Appendix G. Characteristics of Included Studies

A list of acronyms and abbreviations is provided at the end of the report.