# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Robert Carney, Ph.D.^*^
  Washington University
  St. Louis, MO
- Thomas Denberg, M.D., Ph.D., FACP
  Pinnacol Assurance
  Denver, CO
- Glenn Feltz, Psy.D.
  Clinical Psychologist
  Urbana, OH
- Kenneth Freedland, Ph.D.
  Washington University School of Medicine
  St. Louis, MO
- Peter Kaufmann, Ph.D.
  National Heart, Lung, and Blood Institute
  National Institutes of Health
  Bethesda, MD
- Kurt Kroenke, M.D., M.A.C.P
  Indiana University School of Medicine
  VA HSR&D Center for Health Information and Communication
  Indianapolis, IN
- Robert Rich, Jr., M.D., FAAFP^*^
  Community Care of Lower Cape Fear
  Wilmington, NC
- Bruce Rollman, M.D., M.P.H.^*^
  University of Pittsburgh
  Pittsburgh, PA
- Matthew Rudorfer, M.D.
  National Institute of Mental Health
  National Institutes of Health
  Bethesda, MD
- Peter A. Shapiro, M.D.^*^
  Columbia University Medical Center
  New York, NY
- Daichi Shimbo, M.D.^*^
  Columbia University Medical Center
  New York, NY
- Mary Whooley, M.D., FAHA, FACP^*^
  University of California
  San Francisco VA Health Care System
  San Francisco, CA

* Provided input on Draft Report