# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Robert Carney, Ph.D.
  Washington University
  St. Louis, MO
- Thomas Denberg, M.D., Ph.D., FACP
  Pinnacol Assurance
  Denver, CO
- Patrick Farrant
  The Mended Hearts, Inc.
  San Jose, CA
- Glenn Feltz, Psy.D.
  Clinical Psychologist
  Urbana, OH
- Kenneth Freedland, Ph.D.
  Washington University School of Medicine
  St. Louis, MO
- Peter Kaufmann, Ph.D.
  National Heart, Lung, and Blood Institute
  National Institutes of Health
  Bethesda, MD
- Robert Rich, Jr., M.D., FAAFP
  Community Care of Lower Cape Fear
  Wilmington, NC
- Matthew Rudorfer, M.D.
  National Institute of Mental Health
  National Institutes of Health
  Bethesda, MD
- Peter A. Shapiro, M.D.
  Columbia University Medical Center
  New York, NY
- Daichi Shimbo, M.D.
  Columbia University Medical Center
  New York, NY
- Mary Whooley, M.D., FAHA, FACP
  University of California
  San Francisco VA Health Care System
  San Francisco, CA