# Acknowledgments

The authors thank Wei Duan-Porter, M.D., Ph.D., W. Schuyler Jones, M.D., and Megan Chobot, M.S.L.S., for participating in topic refinement; Megan von Isenburg, M.S.L.S., for help with the literature search and retrieval; and Rebecca N. Gray, D.Phil., and Liz Wing, M.A., for editorial assistance.