# Discussion

In this comparative effectiveness review, we reviewed 10 studies described in 21 publications that compared the accuracy of depression screening instruments in post–acute coronary syndrome (ACS) patients (Key Question [KQ] 1) and the comparative safety and effectiveness of depression treatment strategies in post-ACS patients (KQ 2).

This present review is an update of the original 2005 Agency for Healthcare Research and Quality (AHRQ) systematic review,^1^ both reviews found insufficient evidence to support the comparative effectiveness of interventions for improving cardiovascular outcomes, and both reviews recognized the effectiveness of psychosocial interventions and selective serotonin reuptake inhibitors (SSRIs) on improving depression symptoms in patients after myocardial infarction (MI). The original review found insufficient evidence to adequately assess the accuracy of depression screening instruments during the initial hospitalization. In the decade since the 2005 review called for additional research, there are still only 9 more studies added to the evidence base that focus on the broader post-ACS patient population. Both our review and the 2005 review included the Enhancing Recovery In Coronary Heart Disease (ENRICHD) trial since some publications from this trial were included in our current review. We summarize here new evidence and its implications for clinical practice, policy, and needed future research.

## Findings in Relation to Other Reviews on Depression Screening and Treatment After ACS

Both the 2008 American Heart Association (AHA)^24^ and 2009 American Association of Family Physicians (AAFP) Clinical Practice Guidelines^23^ recommend screening for depression in post-MI patients at regular intervals, including during the initial hospitalization, although such recommendations have been met with some controversy.^96, 97^ Other guidelines, such as those from U.S. Preventive Services Task Force (USPSTF) on depression screening in primary care,^20^ recommend implementing screening with “adequate systems in place to ensure accurate diagnosis, effective treatment, and appropriate follow up.” Whether the clinical settings where post-ACS patients are seen can be equipped with such “adequate systems” is an important health care system consideration. Although no specific screening instruments were recommended by the AHA or AAFP guidelines, the Patient Health Questionnaire (PHQ)-9 was used as an example of how screening instruments could be used in clinical practice. Our present review finds that the Beck Depression Inventory (BDI)-II has good sensitivity (90%) and specificity (80%) for major depressive disorder (MDD) during hospitalization after ACS, suggesting that screening can be accomplished in this setting with reasonable accuracy. Data on the accuracy of other screening instruments, including the PHQ, which is popular in general medical settings as well outpatient settings, was very limited. However, the limited available evidence from this review on very brief screenings for depression, including 1–2 items from the BDI-II and 2 items from the PHQ, suggests that such brief screenings may produce comparable diagnostic screening accuracy metrics when using longer screens (e.g., the full BDI-II and PHQ-9). Although we sought evidence on the timing of diagnostic assessment, our findings did not inform the timing of post-ACS depression assessment except to indicate that in-hospital assessment appears to be reasonably accurate in terms of its diagnostic sensitivity and specificity.

Clinical practice guidelines also have recommended that patients “post-MI with a diagnosis of depression” be treated with SSRIs preferentially over tricyclic antidepressants, and that treatment be given “with systems in place to ensure regular followup and monitoring of their treatment response and adherence to treatment.”^23^ The present systematic review did not find any new studies directly comparing SSRIs with tricyclic antidepressants but found two trials supporting enhanced care for patients post-ACS with severe or persistently elevated (two positive depression screens) depressive symptoms. A trial of collaborative care addressing both depression and cardiovascular risk factors (hyperlipidemia, hypertension, diabetes mellitus) improved depression outcomes and intermediate outcomes (e.g., lipid values, blood pressure).^98^ The 2005 AHRQ review^1^ also found that SSRIs and psychosocial interventions improved depression outcomes but not cardiovascular outcomes. Thus, our findings provide support for the recommendation to have systems in place to ensure high-quality treatment, a recommendation that is consistent with the USPSTF recommendation for screening on general medical populations and the American College of Physicians (ACP) policy recommendations^99^ for integrated behavioral health care. Also it should be noted that our findings are generally consistent across sex and ethnic groups.^84, 91^ The Comparison of Depression Interventions after Acute Coronary Syndrome (CODIACS) study focusing on enhanced care did find stronger effects in women.^82^ Although current evidence does not show an overall effect on of depression treatment on cardiovascular events, post-hoc analyses from two studies did show lower major adverse cardiovascular events (MACE) in patients treated with antidepressants, demonstrating a signal that such treatment may lower cardiovascular events. This signal should be considered a hypothesis-generating finding because the analyses did not preserve randomization, and the observed association could be due to chance or biased by unrecognized confounders. Other potential adverse effects (e.g., suicidality, nausea) were not well reported in these studies and it is uncertain if they would differ in post-ACS patients compared to the general adult population.

Note that the prior 2005 AHRQ review^1^ and guidelines^23, 24, 82, 84^ have focused on patients post-MI, but our review extends the population of interest to post-ACS patients. Table 15 summarizes this current review as compared to the prior 2005 AHRQ review.

Table 15 Differences in scope and findings between the 2005^1^ and current evidence reports

| 2005 Report | Current Report
Scope of Key Questions (KQs) | KQs spanned: the prevalence of depression during initial hospitalization and following discharge the association of post-MI depression with outcomes of interest the comparison of outcomes of post-MI patients with and without depression the performance characteristics of instruments used for screening for depression post MI, and the use of cardiac treatments in this patient population. | This current review builds on that original review but focuses on: the diagnostic accuracy of selected depression screening instruments and strategies versus a validated criterion standard in adult patients within 3 months of an ACS event the comparative safety and effectiveness of pharmacologic and nonpharmacologic treatments for depression in adult patients who have received a criterion-based diagnosis of depression or had clinically important depressive symptoms using a validated depression scale, and who are within 3 months of an ACS event
Publication dates for included studies | Inception to 2004 | 2003–2017
Depression diagnosis | Depression defined as symptoms meeting established clinical threshold criteria for depression as measured by validated questionnaires or standardized psychiatric interviews | Depression defined as a criterion-based diagnosis of depression or having clinically important depressive symptoms using a validated depression scale
Cardiac population | Adults who have undergone an acute MI | Adults who have acute coronary syndrome (ACS), which includes both unstable angina and myocardial infarction (MI), and are within 3 months of an identifying ACS event
Prevalence of depression in patients with acute MI | Major depression was reported in approximately 20% of patients during the initial hospitalization for an MI Insufficient data were available to address the question of the prevalence of depression during the initial hospitalization for an acute MI in patients with and without a history of previous depression Most patients with depression during the initial MI hospitalization continued to have depression 1 to 4 months after experiencing an MI | Not addressed
Association of post-MI depression with outcomes | Post-MI depression is associated with a significantly increased risk of death following an MI | Not addressed
What is the performance/accuracy of depression screening instruments in patients with MI/ACS | The BDI tended to be more sensitive to lower levels of depressive symptoms but less sensitive to more severe depression compared to the Hospital and Anxiety Depression Scale (HADS) and the Symptom Checklist-90 Depression scale for depression diagnosis following an acute MI Insufficient data were available to address the performance characteristics of instruments/methods to screen for depression (1) following an acute MI during hospitalization and (2) within 3 months after an acute MI hospitalization | Four depression screening instruments (Beck Depression Inventory II [BDI-II], Geriatric Depression Scale [GDS], HADS, and Patient Health Questionnaire [PHQ]) produce generally acceptable levels for diagnostic sensitivity, specificity, and negative predictive values The BDI-II diagnostic screening performance characteristics were found to have a sensitivity of 90% and specificity of 80%
Do depression treatments improve outcomes in post-MI patients with depression | In post-MI patients with depression, psychosocial interventions improve depression but not other clinical outcomes Selective serotonin reuptake inhibitors improve depression and some surrogate markers of cardiac risk, but no studies of sufficient power address the question of whether this treatment improves survival | Collaborative care interventions, which integrate psychiatric treatment into other clinical settings, improve depression symptoms more than usual care Collaborative care, CBT, or antidepressant medications were similar to usual care in reducing MACE, cardiac mortality, all-cause mortality, repeat ACS, revascularization, or hospitalization in individuals following an ACS event Evidence did not show increased adverse events among post-ACS individuals treated with collaborative care, CBT, or antidepressant medications compared with usual care
Is the use of cardiac medications different in MI patients with and without depression? | Findings were inconsistent with 2 studies showing decreased prescription of beta-blockers and aspirin and 2 studies showing no difference in rates of prescribed discharge medications | Not addressed

Abbreviations: ACS=acute coronary syndrome; BDI=Beck Depression Inventory; CBT=cognitive behavioral therapy; GDS=Geriatric Depression Scale; HADS=Hospital and Anxiety Depression Scale; KQ=Key Question; MACE=major adverse cardiovascular events; MI=myocardial infarction; PHQ=Patient Health Questionnaire

## Applicability

Many studies initially identified in our review either included patients who were not within 3 months from their identifying ACS event, or had not been diagnosed either through a criterion standard or through demonstration of clinically important depressive symptoms using validated depression instruments. We assessed the applicability of our included studies for both Key Questions. For KQ 1, all studies assessed the performance of screening tools for major depressive disorder, and thus are directly applicable to the specific question of interest although have potentially limited applicability to depressive episodes that do not meet criteria for major depression. The strongest evidence was for the BDI-II, a 21-item instrument that takes somewhat longer to complete compared with other commonly used depression screeners (see Table 8). The BDI-II may be feasible to use during hospitalizations but shorter instruments, such as the PHQ-2, are more commonly used in outpatient settings. Further, the BDI-II requires a license to use, which could be a barrier to uptake in practice.

For KQ 2, patients were enrolled with persistently elevated depressive symptoms or after a criterion-based diagnosis of MDD. Study eligibility was determined in two studies ^82, 84^ with the BDI (first edition), an instrument that does not reflect important changes first made to the criterion standard diagnosis of MDD in the Diagnostic and Statistical Manual of Mental Disorders (DSM)-IIIR (1987) and later DSM-IV. The BDI-II (which was evaluated in KQ 1) was updated to reflect these changes. The other two studies used criterion-based diagnoses of MDD. In general medical practice, depression diagnoses are often made without the use of formal criteria. Clinicians would need to use criterion-based diagnoses or document persistently elevated depressive symptoms with a validated instrument, to replicate the outcomes observed in these trials.

Table 16 summarizes the applicability scores across KQs. Note that 3 of the 6 included studies for KQ 1 were described as having narrow eligibility criteria or exclusion of those with comborbidities.

Table 16 Potential issues with applicability of included studies

Category | Issue | Key Question 1 N=6 | Key Question 2 N=4
Population | Narrow eligibility criteria and exclusion of those with comorbidities | 3 | 0
Population | More complex patients than typical of the community | 0 | 1
Population | Run-in period with high exclusion rate for non-adherence or side effects | 0 | 0
Intervention | Diagnostic tools used differently than as recommended or commonly used in practice | 0 | 0
Intervention | Dosing not reflective of current practice | 0 | 0
Intervention | Co-interventions that are likely to modify the effectiveness of therapy | 0 | 2
Intervention | Highly selected intervention team or level of training/proficiency not widely available | 0 | 2
Intervention | Followup not reflective of current practice | 0 | 0
Comparator | Diagnostic tools used differently than as recommended or commonly used in practice | 0 | 0
Comparator | Comparator unclear | 0 | 0
Comparator | Inadequate comparison therapy or use of a substandard alternative therapy | 0 | 0
Outcomes | Composite outcomes that mix outcomes of different significance | 0 | 0
Outcomes | Short-term followup | 0 | 0
Outcomes | Surrogate outcomes | 0 | 0
Setting | Level of care different from that in the community | 0 | 0

## Implications for Clinical and Policy Decisionmaking

MDD is a common comorbid illness post-ACS and is associated with worse cardiovascular outcomes and higher mortality.^17, 18^ The bio-behavioral mechanisms are uncertain but include potential effects on the neuroendocrine system, platelet function, autonomic nervous system activity, adherence to medications, and lifestyle factors such as physical activity. Effective depression treatment may not only improve depression outcomes but also improve quality of life. The impact of depression treatment on cardiovascular outcomes remains uncertain. With the exception of a sequenced approach of CBT plus antidepressants that found no benefit on MACE, depression interventions have not been evaluated in trials with sufficient power to determine effects on cardiovascular outcomes.

Our systematic review has several implications for clinical and policy decisionmaking. Specifically, in KQ 1 we found good performance characteristics for negative predictive value for the BDI-II diagnostic tool across a range of prevalences, which was the screening instrument used most often among included studies. Data on the widely used PHQ (2-, 9-, and 10-item versions) were presented in only one study, which did not compare the PHQ directly to any other screening instruments but found sensitivity and specificity values within a comparable range of those generally reported for the BDI-II. The performance characteristics for the BDI-II in post-ACS patients were similar to the performance in general medical and psychiatric populations.^100^ This suggests that other screening instruments that may be more feasible for use in general medical settings (e.g., shorter, easier to administer and score, no licensing fee) may also perform well in post-ACS patients. Some data within our review^56, 58^ also suggest that very short questionnaires (1–2 questions) may perform similarly to full instruments although the evidence is currently sparse. Both these assumptions need to be confirmed through additional studies. We did not identify studies that directly addressed the timing of screening, and thus there remains uncertainty about the performance of screeners at various times post-ACS.

Our review did not address the effects of depression screening^101^ versus no-screening on downstream depressive or cardiovascular outcomes. However, all intervention studies within KQ 2 identified patients initially by depression screening, and two trials^82, 84^ relied on persistent depressive symptoms to determine eligibility. Thus, coupling screening for identification (using a validated instrument and showing persistent symptoms) with effective treatment seems to improve depressive outcomes.^82^ The USPSTF used this type of evidence and logic model to conclude that evidence supports depression screening in primary care.^20^

Within KQ 2, secondary analyses from the treatment trials showed generally consistent benefit of interventions on depression outcomes by sex and ethnicity.^84, 91^ Importantly, these trials use second-generation antidepressants and/or cognitive behavioral therapy. Thus, recommendations should be limited to these interventions and not generalized to all antidepressants (e.g., tricyclic antidepressants), which may have adverse cardiovascular effects.^102^

The included studies did not show a clear beneficial effect of depression treatment on cardiovascular outcomes in this post-ACS population. However, only one study had sufficient patients and events—and therefore the needed statistical power—to identify a clinically important effect.^91^ Second, two post-hoc analyses suggest the possibility that antidepressant use may be associated with lower cardiovascular events.^82, 84^ In addition, the followup time was limited in the included studies. Clinically, a key issue is that all trials used second-generation antidepressants, and while cardiovascular events were not lower, there was no consistent signal for higher cardiovascular event rates. Therefore, at present, evidence suggests that depression interventions will improve depression outcomes and may not increase negative cardiovascular outcomes.

Data from other studies of unselected patients with depressive disorders, including individual patient-level meta-analyses^103^ show a relationship between greater treatment benefits among patients with more severe depressive symptoms. These data, coupled with the diagnostic approaches in the intervention trials we studied, support a recommendation for careful criterion-based diagnoses and/or diagnoses using validated instruments that show persistent depressive symptoms.

Finally, starting January 1, 2017, the Centers for Medicare and Medicaid Services (CMS) introduced four new payment codes (G codes) that support collaborative care for depression.^104^ The payment by CMS for collaborative care should lower financial barriers to implementing integrated behavioral health for depressed patients, including those post-ACS.

## Limitations of the Systematic Review Process and Evidence Base

Several aspects of the review process may have affected the results. We limited the search to papers published after the cut-off date (March 2004) of the previous AHRQ evidence report on depression post-MI, but incorporated studies from this review.^1^ Our systematic review, however, expanded the patient population of interest to include patients within 3 months of an ACS event (including patients with unstable angina, non-ST-segment elevation myocardial infarction [NSTEMI], and ST-segment elevation myocardial infarction [STEMI]). This meant that studies completed prior to 2004 that targeted the broader post-ACS population might have met our new inclusion criteria but were excluded in the original review. In addition, while the original report included any study which assessed psychometric characteristics, our inclusion criteria limited studies for KQ 1 to those with a criterion standard; however, identifying and treating subthreshold depression in post-ACS patients may still be clinically prudent. Given broad changes in clinical practice over the past decade in both cardiac care (e.g., greater early intervention increased use of dual antiplatelets, greater use of rehabilitation) and depression care (e.g., introduction of new drugs, more behavioral health integration), the impact of missing earlier studies on conclusions about comparative effectiveness of currently used treatment alternatives is unclear, but these changes in populations of interest and required criterion standard made integrating our findings with the previous report challenging.

Our review did not address directly the effectiveness of depression screening in post-ACS patients. To address this issue optimally would require a randomized controlled trial (RCT) that compared the effects of screening with no screening on depression and cardiovascular outcomes. There are few trials of depression screening in any patient population, and the effects of screening alone have been quite limited.^101, 105, 106^

Finally, we did not include studies published in languages other than English, primarily due to resource limitations. However, given the focus of our review on applicability to populations in the United States, and the scope of our KQs, we believe this restriction to be valid.

In addition to the limitations of the systematic review process, the evidence base itself provided additional challenges. The main limitation of the evidence base is the small number of studies directly performed in the post-ACS population of interest using defined criterion standards for comparison (KQ 1) or for identification of patients for assessment of treatment effectiveness (KQ 2). Within these studies, limited data suggest that very short screens such as item 1 (sadness) from the BDI-II^58^ or the two items from the PHQ-2^56^ may perform as well as longer screening tools. If future studies confirm these findings, this could greatly improve the feasibility of screening for depression in post-ACS patients. Secondly, the included KQ 1 studies assessed several cutoff points, either targeting commonly used cutoffs or those determined to be optimal for diagnostic accuracy by the study itself. It is unclear whether the cutoffs should differ for post-ACS patients, although the limited available data suggests this not to be the case.

The evidence for KQ 2 was limited to only four studies. Most of these were underpowered for cardiovascular outcomes, and no studies evaluated several of the interventions identified by key informants and our technical expert panel as being of interest (specifically exercise,^107, 108^ cardiac rehab, nutritional supplements). Some of these interventions may improve cardiac outcomes. For some other interventions also without evidence (e.g., atypical antipsychotics), there are concerns about adverse effects and so studies of these interventions are needed to inform the evidence base. Note that we did not include evidence from observational studies for KQ 2.

## Research Recommendations

Future clinical research, especially comparative effectiveness research—which helps resolve current uncertainties regarding clinical or policy decisions—should receive priority. For both KQs, there are multiple areas of remaining uncertainty based on the existing evidence. Some potential areas for future research informed by our engagement with stakeholders during the topic refinement phase include exploration of how our results for both KQ 1 and KQ 2 apply to highly-related patients; for example, in patients after electing to have coronary artery bypass grafting or percutaneous coronary intervention surgery, or in patients with congestive heart failure. These patient populations were not prioritized for this review but identified as being of interest for future work. Studies on depression screening could focus on differences between screening immediately after an ACS event in the hospital setting compared with later in the outpatient setting, as well as differences based on demographics (e.g., sex, age, ethnicity). More research on the widely used PHQ is also warranted (one study of the PHQ-8 is ongoing^109^).

We also identified gaps in evidence for depression treatments with demonstrated benefit in patients without heart disease. Some of these treatments, such as exercise,^110^ cardiac rehabilitation and omega-3 fatty acid supplements^96, 111, 112^ have the potential to benefit both depression and cardiac outcomes. Interventions that have the evidence to directly benefit both conditions may be particularly promising interventions to prioritize for future research. In addition, evidence from studies that explore other interventions such as other forms of psychotherapy and CBT are needed.

As noted above, our review signaled that antidepressants may benefit cardiovascular outcomes in addition to depression, but these findings are observational and not definitive. Further trials however—and specifically longer-term studies—are needed which have cardiovascular outcomes as the primary outcome of interest with the appropriate statistical power to detect an effect. Such trials will need to be relatively large and so value-of-information studies done in advance could help prioritize such studies and inform their design.^113^ Given the scarcity of evidence from RCTs, insight from large high-quality observational studies may also inform the remaining uncertainties and help prioritize needed future research. Similar to KQ 1, research studies which focused on specific subgroups of interest (e.g., older patients, women, minorities) is needed.

Current general MDD guidelines,^99^ although not specific to post-ACS patients, recommend second-generation antidepressant or CBT as first line treatment for depression. All of our studies compared treatment strategies to usual care. We therefore were unable to make direct head-to-head comparisons of the active interventions. Although such studies would increase the strength of evidence, possibly more valuable research would focus on the comparisons of antidepressant treatment with CBT compared to antidepressant treatment alone. Some data suggest this may be more effective for depression in general, and given the psychosocial stress of post-ACS and the signal for possible cardiovascular benefit from secondary analyses on antidepressant, testing this combination might be a high priority.

## Conclusions

Among several depression screening tools, the BDI is the most studied. Existing tools miss less than 3 percent of patients with depression (high negative predictive value: 97%), but less than 50 percent of patients who screen positive actually have the condition (low positive predictive value: <50%). Enhanced care interventions and a strategy using CBT plus second generation antidepressant medication for patients with severe depression or partial response to CBT improve depressive outcomes more than usual care. Given the inconsistency and imprecision of findings, and the small number of studies evaluating cardiovascular outcomes, the effects of depression interventions on such cardiovascular outcomes is uncertain.