# Appendix G Characteristics of Included Studies

Appendix Table G1 Characteristics of included studies for KQ 1

Study Companion Article | Study Design Location Setting | Patient Demographics | Purpose | Criterion Standard versus Tool(s) Assessed | Diagnostic Accuracy Measures
Bambauer, 2005^1^ | Observational U.S. Inpatient | N completed: 79 Mean age:; - Arm 1: 60.7 (SD 9.8); - Arm 2: 59.9 (SD 10.2); % Female:; - Arm 1: 35%; - Arm 2: 31% | To determine the effects of providing post-ACS depression care on depressive symptoms and healthcare costs. | [underlined: Criterion standard] PRIME-MD, DSM-IV [underlined: Tool assessed] Hospital Anxiety and Depression Scale-14 (HADS-14) | PPV
Bunevicius, 2012^2^ | Observational U.K./Europe Cardiac rehabilitation clinic | N completed: 522 Mean age: 58 % Female: 28% | To evaluate the internal consistency and psychometric properties of the HADS and the BDI-II for screening of major depressive episodes in patients with coronary artery disease undergoing rehabilitation. | [underlined: Criterion standard] Structured Mini International Neuropsychiatric Interview, DSM-IV [underlined: Tools assessed] Hospital Anxiety and Depression Scales:; - HADS-14; - HADS-Anxiety Subscale; - HADS-Depression Subscale; BDI-II | Sensitivity Specificity PPV NPV AUC
Frasure-Smith, 2008^3^ | Observational Canada Inpatient | N completed: 804 Mean age: 60 (SD 10.6) % Female: 19.3% | To assess the 2-year cardiac prognostic importance of the DSM-IV–based diagnoses of major depressive disorder and generalized anxiety disorder and self-report measures of anxiety and depression and their co-occurrence. | [underlined: Criterion standard] Structured Clinical Interview for DSM-IV [underlined: Tools assessed] HADS-Anxiety Subscale BDI-II | Sensitivity Specificity AUC
Huffman, 2006^4^ [underlined: Companion] Huffman, 2010^5^ | Observational U.S. Inpatient | N completed: 131 Mean age: 62.2 (SD 12.6) % Female: 20% | To determine the ability of 3 questions from the BDI-II to detect major depressive disorder in a cohort of patients hospitalized for acute myocardial infarction. | [underlined: Criterion standard] Structured Clinical Interview for DSM-IV-TR Axis I Disorders [underlined: Tool assessed] BDI-II | Sensitivity Specificity PPV NPV AUC
Low, 2007^6^ | Observational Canada Inpatient | N completed: 119 Mean age: 62.9 (SD 11.6) % Female: 25% | To examine the sensitivity and specificity for participants’ scores on 2 widely-used depression inventories with older adults relative to the Structured Clinical Interview for DSM-IV-TR Axis I Disorders, as well as recommend appropriate cut scores for the 2 measures for identifying post-myocardial infarction or unstable angina patients with depression. | [underlined: Criterion standard] PRIME-MD, DSM-IV [underlined: Tools assessed] Geriatric Depression Scale BDI-II | Sensitivity Specificity PPV NPV AUC
McGuire, 2013^7^ | Observational U.S. Inpatient | N completed: 100 Mean age:; - Depressed: 56.6 (SD 13.4; - Nondepressed: 65.52 (SD 11.2); % Female: 31% | To evaluate nurse-administered versions of the Patient Health Questionnaire for depression screening in patients hospitalized for acute coronary syndrome. | [underlined: Criterion standard] Depression interview Structured Hamilton Scale, DSM-IV [underlined: Tools assessed] Patient Health Questionnaire:; - PHQ-2; - PHQ-9; - PHQ-10 | Sensitivity Specificity PPV NPV AUC

Abbreviations: ACS=acute coronary syndrome; AUC=area under the curve; BDI=Beck Depression Inventory; DSM-IV=Diagnostic and Statistical Manual of Mental Disorders, 4th edition; DSM-IV-TR=Diagnostic and Statistical Manual of Mental Disorders, 4th edition, Text Revision; HADS=Hospital Anxiety and Depression Scale; KQ=key question; NPV=negative predicted value; PHQ=Patient Health Questionnaire; PPV=positive predicted value; PRIME-MD=Primary Care Evaluation of Mental Disorders; SD=standard deviation.

Appendix Table G2 Characteristics of included studies for KQ 2

Study Acronym Companion Article(s) | Study Design Location Patient Demographics Quality Rating | Purpose Criteria for Diagnosis of Depression | Intervention versus Comparator | Outcomes Subgroups
Berkman, 2003^8^ ENRICHD [underlined: Companions] Banankhah, 2015^9^ Roest, 2013^10^ Saab, 2009^11^ Cowan, 2008^12^ Mendes de Leon, 2006^13^ Schneiderman, 2004^14^ Carney, 2004^15^ | RCT U.S. N enrolled: 2,481 Mean age:; - Arm 1: 61 (SD 12.5); - Arm 2: 61 (SD 12.5); % Female:; - Arm 1: 44%; - Arm 2: 43%; Good quality | [underlined: Purpose] To determine whether mortality and recurrent infarction are reduced by treatment of depression and low perceived social support with CBT supplemented with an SSRI antidepressant when indicated, in patients enrolled within 28 days post-MI. [underlined: Diagnosis] The Depression Interview and Structured Hamilton (DISH) was used to diagnose current depressive episodes according to DSM-IV) criteria. The DISH also yields a depression severity score on the 17-item Hamilton Rating Scale for Depression (HRSD). In addition to the DISH, the BDI was administered. A score of 10 or higher is the threshold for considering clinical depression. | [underlined: Enhanced care delivery] Individual CBT sessions plus group therapy when feasible, with SSRIs for patients scoring higher than 24 on HRSD or having <50% reduction in the BDI scores after 5 weeks. [underlined: Usual care] Patients in usual care received only the care provided by their physicians. This included antidepressant use at baseline in 4.8% of patients, 13.4% at 6 months and 20.6% by the end of the study. | [underlined: Clinical outcomes] MACE composite (death or nonfatal MI) Total mortality Cardiac mortality Repeat ACS event Revascularization procedures Depression-related outcomes: response or remission of depressive symptoms [underlined: Healthcare utilization] Cardiovascular hospitalizations [underlined: Quality of life] SF-12 Physical Component Summary SF-12 Mental Component Summary Life Satisfaction Scale (8 items; score range 0–24) [underlined: Subgroups] Race/ethnicity Sex
Davidson, 2013^16^ CODIACS | RCT U.S. N enrolled: 150 Mean age Arm 1: 59.2 (SD 9.7) Arm 2: 60 (SD 11.1) % Female Arm 1: 41% Arm 2: 43% Good quality | [underlined: Purpose] To determine the effects of providing post-ACS depression care on depressive symptoms and health care costs. [underlined: Diagnosis] BDI ≥10 on 2 occasions or >15 on one occasion. | [underlined: Enhanced care delivery] Centralized, stepped, patient-preference-based depression care; team care; centralized patient services team and/or local MD/nurse practitioner prescribed antidepressants. Symptom monitoring with PHQ-9 and stepped care. [underlined: Usual care] Primary care physician and/or cardiologist notified by letter of depression symptoms. No restrictions on care. | [underlined: Clinical outcomes] Revascularization procedures Depression-related outcomes: response or remission of depressive symptoms [underlined: Healthcare utilization] All hospitalizations [underlined: Costs] Total healthcare costs [underlined: Subgroups] Sex
Davidson, 2010^17^ COPES [underlined: Companions] Ye, 2014^18^ Kronish, 2012^19^ | RCT U.S. N enrolled: 157 Mean age Arm 1: 61.1 (SD 10.6) Arm 2: 59.3 (SD 10.6) % Female Arm 1: 53% Arm 2: 54% Fair quality | [underlined: Purpose] To determine the acceptability and efficacy of enhanced depression treatment in patients with ACS. [underlined: Diagnosis] Trial eligibility required a score of 10 or higher on the BDI on assessments within 1 week of hospitalization for ACS and 3 months later. | [underlined: Enhanced care delivery] Collaborative care including enhanced care by a team of providers (nurse specialist, psychologist, social worker, and/or psychiatrist), patient choice of pharmacotherapy and/or psychotherapy (problem-solving therapy), stepped care approach with symptom severity reviewed every 8 weeks and treatment augmented by protocol, and routine monitoring of depression symptoms using a standardized instrument. [underlined: Usual care] For patients randomized to usual care only: The control condition for the trial was usual care, as defined by the patient’s treating physicians. Physicians of the intervention and usual care patients were informed that their patients were participating in a trial and that they had elevated depressive symptoms; physicians were also told whether the patient met the criteria for a major depressive episode. | [underlined: Clinical outcomes] MACE events MACE composite (hospitalization for ACS) Depression-related outcomes: response or remission of depressive symptoms [underlined: Healthcare utilization] Cardiac medication adherence [underlined: Adverse effects of treatment] [underlined: Subgroups] Race/ethnicity Sex
van Melle, 2007^20^ MIND-IT [underlined: Companion] Zuidersma 2013^21^ | RCT U.K./Europe N enrolled: 331 Mean age Arm 1: 58.6 (SD 11.5) Arm 2: 57.5 (SD 10.6) % Female Arm 1: 24% Arm 2: 26% Good quality | [underlined: Purpose] To evaluate the effects of antidepressant treatment compared with usual care in an effectiveness study. [underlined: Diagnosis] BDI ≥10 plus met WHO ICD-10 criteria for current depressive episode [CIDI interview]. | [underlined: Medical therapy] First-choice treatment: mirtazapine. If refusal or insufficient treatment response after 8 weeks, open treatment with citalopram was offered. Treatment response ≥50% reduction on the HDRS or a HDRS score at 8 weeks of ≤9. The third option was “tailored treatment,” which was at the discretion of the clinical psychiatrist (e.g., SSRI, psychotherapy). Scheduled to visit the psychiatrist on average once a month during the treatment period of 6 months. [underlined: Usual care] Psychiatric treatment outside the study was recorded, but no treatment was offered by the MIND-IT investigators. Patients NOT informed of diagnosis. | [underlined: Clinical outcomes] MACE composite (death or nonfatal MI) Total mortality Cardiac mortality Repeat ACS event Revascularization procedures Depression-related outcomes: response or remission of depressive symptoms [underlined: Healthcare utilization] Cardiovascular hospitalizations [underlined: Quality of life] Health Complaints Scale Physical health (RAND-36) score Mental health (RAND-36) score Complete disability Partial disability [underlined: Subgroups] None

Abbreviations: ACS=acute coronary syndrome; BDI=Beck Depression Inventory; CBT=cognitive behavioral therapy; CIDI=Composite International Diagnostic Interview; CODIACS=Comparison of Depression Interventions after Acute Coronary Syndrome; COPES=Coronary Patients Evaluation Study; DISH=Depression Interview and Structured Hamilton; DSM-IV=Diagnostic and Statistical Manual of Mental Disorders, 4th edition; ENRICHD=Enhancing Recovery in Coronary Heart Disease study; HCS=Health Complaints Scale; HDRS=Hamilton Depression Rating Scale; HRSD=Hamilton Rating Scale for Depression; ICD-10=International Classification of Disease, Tenth Edition; MACE=major adverse cardiac events; MI=myocardial infarction; MIND-IT=Myocardial Infarction and Depression-Intervention Trial; PHQ=Patient Health Questionnaire; RCT=randomized controlled trial; SD=standard deviation; SSRI=selective serotonin reuptake inhibitor; WHO=World Health Organization.

## References to Appendix G

1 Bambauer KZ, Locke SE, Aupont O, . Using the Hospital Anxiety and Depression Scale to screen for depression in cardiac patients. Gen Hosp Psychiatry. 2005;27(4):275–84. doi: 10.1016/j.genhosppsych.2005.03.002. PMID: 2005-08290-009.15993261
2 Bunevicius A, Staniute M, Brozaitiene J, . Diagnostic accuracy of self-rating scales for screening of depression in coronary artery disease patients. J Psychosom Res. 2012 Jan;72(1):22–5. doi: 10.1016/j.jpsychores.2011.10.006. PMID: 22200518.22200518
3 Frasure-Smith N, Lesperance F. Depression and anxiety as predictors of 2-year cardiac events in patients with stable coronary artery disease. Arch Gen Psychiatry. 2008 Jan;65(1):62–71. doi: 10.1001/archgenpsychiatry.2007.4. PMID: 18180430.18180430
4 Huffman JC, Smith FA, Blais MA, . Rapid screening for major depression in post-myocardial infarction patients: an investigation using Beck Depression Inventory II items. Heart. 2006 Nov;92(11):1656–60. doi: 10.1136/hrt.2005.087213. PMID: 16644855.16644855
5 Huffman JC, Doughty CT, Januzzi JL, . Screening for major depression in post-myocardial infarction patients: Operating characteristics of the Beck-Depression Inventory-II. Int J Psychiatry Med. 2010;40(2):187–97. doi: 10.2190/PM.40.2.e. PMID: 2010-18061-005.20848875
6 Low GD, Hubley AM. Screening for depression after cardiac events using the Beck Depression Inventory-II and the Geriatric Depression Scale. Social Indicators Research. 2007;82(3):527–48. doi: 10.1007/s11205-006-9049-3. PMID: 2008-08604-008.
7 McGuire AW, Eastwood JA, Macabasco-O’Connell A, . Depression screening: utility of the patient health questionnaire in patients with acute coronary syndrome. Am J Crit Care. 2013 Jan;22(1):12–9. doi: 10.4037/ajcc2013899. PMID: 23283084.23283084
8 Berkman LF, Blumenthal J, Burg M, . Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. 2003 Jun 18;289(23):3106–16. doi: 10.1001/jama.289.23.3106. PMID: 12813116.12813116
9 Banankhah SK, Friedmann E, Thomas S. Effective treatment of depression improves post-myocardial infarction survival. World J Cardiol. 2015 Apr 26;7(4):215–23. doi: 10.4330/wjc.v7.i4.215. PMID: 25914790.25914790
10 Roest AM, Carney RM, Freedland KE, . Changes in cognitive versus somatic symptoms of depression and event-free survival following acute myocardial infarction in the Enhancing Recovery In Coronary Heart Disease (ENRICHD) study. J Affect Disord. 2013 Jul;149(1–3):335–41. doi: 10.1016/j.jad.2013.02.008. PMID: 23489396.23489396
11 Saab PG, Bang H, Williams RB, . The impact of cognitive behavioral group training on event-free survival in patients with myocardial infarction: the ENRICHD experience. J Psychosom Res. 2009 Jul;67(1):45–56. doi: 10.1016/j.jpsychores.2009.01.015. PMID: 19539818.19539818
12 Cowan MJ, Freedland KE, Burg MM, . Predictors of treatment response for depression and inadequate social support--the ENRICHD randomized clinical trial. Psychother Psychosom. 2008;77(1):27–37. doi: 10.1159/000110057. PMID: 18087205.18087205
13 Mendes de Leon CF, Czajkowski SM, Freedland KE, . The effect of a psychosocial intervention and quality of life after acute myocardial infarction: the Enhancing Recovery in Coronary Heart Disease (ENRICHD) clinical trial. J Cardiopulm Rehabil. 2006 Jan–Feb;26(1):9–13; quiz 4–5. PMID: 16617220.16617220
14 Schneiderman N, Saab PG, Catellier DJ, . Psychosocial treatment within sex by ethnicity subgroups in the Enhancing Recovery in Coronary Heart Disease clinical trial. Psychosom Med. 2004 Jul–Aug;66(4):475–83. doi: 10.1097/01.psy.0000133217.96180.e8. PMID: 15272091.15272091
15 Carney RM, Blumenthal JA, Freedland KE, . Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. 2004 Jul–Aug;66(4):466–74. doi: 10.1097/01.psy.0000133362.75075.a6. PMID: 15272090.15272090
16 Davidson KW, Bigger JT, Burg MM, . Centralized, stepped, patient preference-based treatment for patients with post-acute coronary syndrome depression: CODIACS vanguard randomized controlled trial. JAMA Intern Med. 2013 Jun 10;173(11):997–1004. doi: 10.1001/jamainternmed.2013.915. PMID: 23471421.23471421
17 Davidson KW, Rieckmann N, Clemow L, . Enhanced depression care for patients with acute coronary syndrome and persistent depressive symptoms: coronary psychosocial evaluation studies randomized controlled trial. Arch Intern Med. 2010 Apr 12;170(7):600–8. doi: 10.1001/archinternmed.2010.29. PMID: 20386003.20386003
18 Ye S, Shaffer JA, Rieckmann N, . Long-term outcomes of enhanced depression treatment in patients with acute coronary syndromes. Am J Med. 2014 Oct;127(10):1012–6. doi: 10.1016/j.amjmed.2014.05.004. PMID: 24835038.24835038
19 Kronish IM, Rieckmann N, Burg MM, . The effect of enhanced depression care on adherence to risk-reducing behaviors after acute coronary syndromes: findings from the COPES trial. Am Heart J. 2012 Oct;164(4):524–9. doi: 10.1016/j.ahj.2012.07.024. PMID: 23067910.23067910
20 van Melle JP, de Jonge P, Honig A, . Effects of antidepressant treatment following myocardial infarction. Br J Psychiatry. 2007 Jun;190:460–6. doi: 10.1192/bjp.bp.106.028647. PMID: 17541103.17541103
21 Zuidersma M, Conradi HJ, van Melle JP, . Depression treatment after myocardial infarction and long-term risk of subsequent cardiovascular events and mortality: a randomized controlled trial. J Psychosom Res. 2013 Jan;74(1):25–30. doi: 10.1016/j.jpsychores.2012.08.015. PMID: 23272985.23272985