# Appendix F Key to Included Primary and Companion Articles

Appendix Table F1 Key to included primary and companion articles

Study Designation | Primary Abstracted Article | Companion Articles
CODIACS (Comparison of Depression Interventions after Acute Coronary Syndrome) | Davidson, 2013^1^ | ^*^Whang, 2012^2^
COPES (Coronary Patients Evaluation Study) | Davidson, 2010^3^ | Ye, 2014^4^ Kronish, 2012^5^
ENRICHD (Enhancing Recovery In Coronary Heart Disease) | Berkman, 2003^6^ | Banankhah, 2015^7^ Roest, 2013^8^ Saab, 2009^9^ Cowan, 2008^10^ Mendes de Leon, 2006^11^ Schneiderman, 2004^12^ Carney, 2004^13^ ^*^ENRICHD investigators, 2001^14^
ESCAPE (Epidemiological Study of Acute Coronary Syndromes and the Pathophysiology of Emotions) | Frasure-Smith, 2008^15^ | None
MIND-IT (Myocardial INfarction and Depression–Intervention Trial) | van Melle, 2007^16^ | Zuidersma, 2013^17^ ^*^van den Brink, 2002^18^
None | Bambauer, 2005^19^ | None
None | Bunevicius, 2012^20^ | None
None | Huffman, 2006^21^ | Huffman, 2010^22^
None | Low, 2007^23^ | None
None | McGuire, 2013^24^ | None

* Companion articles marked with an asterisk (n=3) did not individually meet criteria for inclusion but were considered for supplemental information (e.g., methods data pertinent to an included study).

## References to Appendix F

1 Davidson KW, Bigger JT, Burg MM, . Centralized, stepped, patient preference-based treatment for patients with post-acute coronary syndrome depression: CODIACS vanguard randomized controlled trial. JAMA Intern Med. 2013 Jun 10;173(11):997–1004. doi: 10.1001/jamainternmed.2013.915. PMID: 23471421.23471421
2 Whang W, Burg MM, Carney RM, . Design and baseline data from the vanguard of the Comparison of Depression Interventions after Acute Coronary Syndrome (CODIACS) randomized controlled trial. Contemp Clin Trials. 2012 Sep;33(5):1003–10. doi: 10.1016/j.cct.2012.05.005. PMID: 22640924.22640924
3 Davidson KW, Rieckmann N, Clemow L, . Enhanced depression care for patients with acute coronary syndrome and persistent depressive symptoms: coronary psychosocial evaluation studies randomized controlled trial. Arch Intern Med. 2010 Apr 12;170(7):600–8. doi: 10.1001/archinternmed.2010.29. PMID: 20386003.20386003
4 Ye S, Shaffer JA, Rieckmann N, . Long-term outcomes of enhanced depression treatment in patients with acute coronary syndromes. Am J Med. 2014 Oct;127(10):1012–6. doi: 10.1016/j.amjmed.2014.05.004. PMID: 24835038.24835038
5 Kronish IM, Rieckmann N, Burg MM, . The effect of enhanced depression care on adherence to risk-reducing behaviors after acute coronary syndromes: findings from the COPES trial. Am Heart J. 2012 Oct;164(4):524–9. doi: 10.1016/j.ahj.2012.07.024. PMID: 23067910.23067910
6 Berkman LF, Blumenthal J, Burg M, . Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. 2003 Jun 18;289(23):3106–16. doi: 10.1001/jama.289.23.3106. PMID: 12813116.12813116
7 Banankhah SK, Friedmann E, Thomas S. Effective treatment of depression improves post-myocardial infarction survival. World J Cardiol. 2015 Apr 26;7(4):215–23. doi: 10.4330/wjc.v7.i4.215. PMID: 25914790.25914790
8 Roest AM, Carney RM, Freedland KE, . Changes in cognitive versus somatic symptoms of depression and event-free survival following acute myocardial infarction in the Enhancing Recovery In Coronary Heart Disease (ENRICHD) study. J Affect Disord. 2013 Jul;149(1–3):335–41. doi: 10.1016/j.jad.2013.02.008. PMID: 23489396.23489396
9 Saab PG, Bang H, Williams RB, . The impact of cognitive behavioral group training on event-free survival in patients with myocardial infarction: the ENRICHD experience. J Psychosom Res. 2009 Jul;67(1):45–56. doi: 10.1016/j.jpsychores.2009.01.015. PMID: 19539818.19539818
10 Cowan MJ, Freedland KE, Burg MM, . Predictors of treatment response for depression and inadequate social support--the ENRICHD randomized clinical trial. Psychother Psychosom. 2008;77(1):27–37. doi: 10.1159/000110057. PMID: 18087205.18087205
11 Mendes de Leon CF, Czajkowski SM, Freedland KE, . The effect of a psychosocial intervention and quality of life after acute myocardial infarction: the Enhancing Recovery in Coronary Heart Disease (ENRICHD) clinical trial. J Cardiopulm Rehabil. 2006 Jan–Feb;26(1):9–13; quiz 4–5. PMID: 16617220.16617220
12 Schneiderman N, Saab PG, Catellier DJ, . Psychosocial treatment within sex by ethnicity subgroups in the Enhancing Recovery in Coronary Heart Disease clinical trial. Psychosom Med. 2004 Jul–Aug;66(4):475–83. doi: 10.1097/01.psy.0000133217.96180.e8. PMID: 15272091.15272091
13 Carney RM, Blumenthal JA, Freedland KE, . Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. 2004 Jul–Aug;66(4):466–74. doi: 10.1097/01.psy.0000133362.75075.a6. PMID: 15272090.15272090
14 Enhancing recovery in coronary heart disease (ENRICHD): baseline characteristics. Am J Cardiol. 2001 Aug 01;88(3):316–22. PMID: 11472719.11472719
15 Frasure-Smith N, Lesperance F. Depression and anxiety as predictors of 2-year cardiac events in patients with stable coronary artery disease. Arch Gen Psychiatry. 2008 Jan;65(1):62–71. doi: 10.1001/archgenpsychiatry.2007.4. PMID: 18180430.18180430
16 van Melle JP, de Jonge P, Honig A, . Effects of antidepressant treatment following myocardial infarction. Br J Psychiatry. 2007 Jun;190:460–6. doi: 10.1192/bjp.bp.106.028647. PMID: 17541103.17541103
17 Zuidersma M, Conradi HJ, van Melle JP, . Depression treatment after myocardial infarction and long-term risk of subsequent cardiovascular events and mortality: a randomized controlled trial. J Psychosom Res. 2013 Jan;74(1):25–30. doi: 10.1016/j.jpsychores.2012.08.015. PMID: 23272985.23272985
18 van den Brink RH, van Melle JP, Honig A, . Treatment of depression after myocardial infarction and the effects on cardiac prognosis and quality of life: rationale and outline of the Myocardial INfarction and Depression-Intervention Trial (MIND-IT). Am Heart J. 2002 Aug;144(2):219–25. PMID: 12177637.12177637
19 Bambauer KZ, Locke SE, Aupont O, . Using the Hospital Anxiety and Depression Scale to screen for depression in cardiac patients. Gen Hosp Psychiatry. 2005;27(4):275–84. doi: 10.1016/j.genhosppsych.2005.03.002. PMID: 2005-08290-009.15993261
20 Bunevicius A, Staniute M, Brozaitiene J, . Diagnostic accuracy of self-rating scales for screening of depression in coronary artery disease patients. J Psychosom Res. 2012 Jan;72(1):22–5. doi: 10.1016/j.jpsychores.2011.10.006. PMID: 22200518.22200518
21 Huffman JC, Smith FA, Blais MA, . Rapid screening for major depression in post-myocardial infarction patients: an investigation using Beck Depression Inventory II items. Heart. 2006 Nov;92(11):1656–60. doi: 10.1136/hrt.2005.087213. PMID: 16644855.16644855
22 Huffman JC, Doughty CT, Januzzi JL, . Screening for major depression in post-myocardial infarction patients: Operating characteristics of the Beck-Depression Inventory-II. Int J Psychiatry Med. 2010;40(2):187–97. doi: 10.2190/PM.40.2.e. PMID: 2010-18061-005.20848875
23 Low GD, Hubley AM. Screening for depression after cardiac events using the Beck Depression Inventory-II and the Geriatric Depression Scale. Social Indicators Research. 2007;82(3):527–48. doi: 10.1007/s11205-006-9049-3. PMID: 2008-08604-008.
24 McGuire AW, Eastwood JA, Macabasco-O’Connell A, . Depression screening: utility of the patient health questionnaire in patients with acute coronary syndrome. Am J Crit Care. 2013 Jan;22(1):12–9. doi: 10.4037/ajcc2013899. PMID: 23283084.23283084