# Appendix E List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reasons cited. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## Not a full publication, article retracted/withdrawn, or full publication not available

Antidepressant Use Reduces Risk of Heart Attack in Depressed Patients. Drug Benefit Trends. 2005;17(8):353–353.
Moon, KT. Patient preference in treating depression in persons with ACS. American Family Physician. 2010;82(7):828.
Price, JR. Treating low perceived social support and depression after myocardial infarction does not increase event-free survival. Evidence Based Mental Health. 2004;7(1):22–22. PMID: 106782722.14769666
Treating depression after acute coronary syndrome. Bmj. 2013;346:f1567. DOI: 10.1136/bmj.f1567. PMID: 23482981.23482981

## Not available in English

Pinho, MX, Custodio, O, Makdisse, M, Carvalho, AC. [Reliability and validity of the geriatric depression scale in elderly individuals with coronary artery disease]. Arq Bras Cardiol. 2010;94(5):570–9. PMID: 20428716.20428716
Tiringer, I, Simon, A, Herrfurth, D, Suri, I, Szalai, K, Veress, A. [Occurrence of anxiety and depression disorders after acute cardiac events during hospital rehabilitation. Application of the Hospital Anxiety and Depression Scale as a screening instrument]. Psychiatr Hung. 2008;23(6):430–43. PMID: 19218625.19218625

## Not original peer-reviewed data

Azevedo, RDM, Roest, AM, Carney, RM, Denollet, J, Freedland, KE, Grace, SL, Hosseini, SH, Lane, DA, Parakh, K, Pilote, L, Jonge, PD. A bifactor model of the beck depression inventory and its association with medical prognosis after myocardial infarction. Health Psychology. 2016;35(6):614–624.26901082
Ballinger, RM. The heart of the matter. European Pharmaceutical Contractor. 2012;(SUMMER):54–59.
Colquhoun, DM, Bunker, SJ, Clarke, DM, Glozier, N, Hare, DL, Hickie, IB, Tatoulis, J, Thompson, DR, Tofler, GH, Wilson, A, Branagan, MG. Screening, referral and treatment for depression in patients with coronary heart disease. Med J Aust. 2013;198(9):483–4. PMID: 23682890.23682890
Huffman, JC, Beach, SR, Suarez, L, Mastromauro, CA, DuBois, CM, Celano, CM, Rollman, BL, Januzzi, JL. Design and baseline data from the Management of Sadness and Anxiety in Cardiology (MOSAIC) randomized controlled trial. Contemp Clin Trials. 2013;36(2):488–501. DOI: 10.1016/j.cct.2013.09.012. PMID: 24090821.24090821
Jolly, K, Lip, GY, Sandercock, J, Greenfield, SM, Raftery, JP, Mant, J, Taylor, R, Lane, D, Lee, KW, Stevens, AJ. Home-based versus hospital-based cardiac rehabilitation after myocardial infarction or revascularisation: design and rationale of the Birmingham Rehabilitation Uptake Maximisation Study (BRUM): a randomised controlled trial [ISRCTN72884263]. BMC Cardiovasc Disord. 2003;3:10. DOI: 10.1186/1471-2261-3-10. PMID: 12964946.12964946
Kim, JM, Bae, KY, Kang, HJ, Kim, SW, Shin, IS, Hong, YJ, Kim, JH, Shin, HY, Ahn, Y, Kim, JK, Jeong, MH, Yoon, JS. Design and Methodology for the Korean Observational and Escitalopram Treatment Studies of Depression in Acute Coronary Syndrome: K-DEPACS and EsDEPACS. Psychiatry Investig. 2014;11(1):89–94. DOI: 10.4306/pi.2014.11.1.89. PMID: 24605129.24605129
Kotb, A, Hsieh, S, Wells, GA. The effect of telephone support interventions on coronary artery disease (CAD) patient outcomes during cardiac rehabilitation: a systematic review and meta-analysis. PLoS One. 2014;9(5):e96581. DOI: 10.1371/journal.pone.0096581. PMID: 24798429.24798429
Lin, Hsin-hua. Racial/ethnic differences in depressive symptoms and treatment effect among patients with myocardial infarction from the enhancing recovery in coronary heart disease (ENRICHD) trial. 2013;73.
Mavrides, N, Nemeroff, CB. Treatment of affective disorders in cardiac disease. Dialogues in Clinical Neuroscience. 2015;17(2):127–140.26246788
McGuire, Anthony William. Depression screening by nurses in hospitalized Acute Coronary Syndrome patients. 2012;73:221–221.
Mellédo, Jean-Michel, Perez-Parada, Jorge. Selective serotonin reuptake inhibitors (SSRIs) and depression after myocardial infarction (MI). Journal of Psychiatry & Neuroscience. 2005;30(2):152–152. PMID: 2005-04831-009.15798791 Oguzkurt L. Ultrasonographic anatomy of the lower extremity superficial veins. Diagn Interv Radiol. 2012;18(4):423–30. PMID: 22427019.22427019
Norlund, F, Olsson, EM, Burell, G, Wallin, E, Held, C. Treatment of depression and anxiety with internet-based cognitive behavior therapy in patients with a recent myocardial infarction (U-CARE Heart): study protocol for a randomized controlled trial. Trials. 2015;16:154. DOI: 10.1186/s13063-015-0689-y. PMID: 25873137.25873137
Oldroyd, JC, Cyril, S, Wijayatilaka, BS, O’Neil, A, McKenzie, DP, Zavarsek, S, Sanderson, K, Hare, DL, Fisher, AJ, Forbes, AB, Barr Taylor, C, Clarke, DM, Meredith, IT, Oldenburg, B. Evaluating the impact of depression, anxiety & autonomic function on health related quality of life, vocational functioning and health care utilisation in acute coronary syndrome patients: the ADVENT study protocol. BMC Cardiovasc Disord. 2013;13:103. DOI: 10.1186/1471-2261-13-103. PMID: 24237848.24237848
O’Neil, A, Hawkes, AL, Chan, B, Sanderson, K, Forbes, A, Hollingsworth, B, Atherton, J, Hare, DL, Jelinek, M, Eadie, K, Taylor, C. B, Oldenburg, B. A randomised, feasibility trial of a tele-health intervention for acute coronary syndrome patients with depression (‘MoodCare’): study protocol. BMC Cardiovasc Disord. 2011;11:8. DOI: 10.1186/1471-2261-11-8. PMID: 21349204.21349204
Parashar, S, Rumsfeld, JS. Citalopram, but not interpersonal psychotherapy, improves major depression in people with coronary artery disease. Evidence Based Mental Health. 2007;10(3):80–80. PMID: 105971235.17652562
Parthasarathy, Sairam, Shetty, Safal, Combs, Daniel. Mend the mind and mind the ‘MCC’. Sleep: Journal of Sleep and Sleep Disorders Research. 2015;38(7):1001–1003. DOI: 10.5665/sleep.4794.
Pourafkari, N, Pourafkari, L, Nader, ND. Electroconvulsive therapy for depression following acute coronary syndromes: A concern for the anesthesiologist. Journal of Clinical Anesthesia. 2016;31:223–228.27185716
Ramamurthy, G, Trejo, E, Faraone, SV. Depression treatment in patients with coronary artery disease: a systematic review. Prim Care Companion CNS Disord. 2013;15. (5). DOI: 10.4088/PCC.13r01509. PMID: 24511449.24511449
Richards, SH, Dickens, C, Anderson, R, Richards, DA, Taylor, RS, Ukoumunne, OC, Kessler, D, Turner, K, Kuyken, W, Gandhi, M, Knight, L, Gibson, A, Davey, A, Warren, F, Winder, R, Wright, C, Campbell, J. Assessing the effectiveness of enhanced psychological care for patients with depressive symptoms attending cardiac rehabilitation compared with treatment as usual (CADENCE): study protocol for a pilot cluster randomised controlled trial. Trials. 2016;17:59. DOI: 10.1186/s13063-016-1184-9. PMID: 26830029.26830029
Sorensenf, C, Friis-Hasche, E, Haghfelt, T, Bech, P. Postmyocardial infarction mortality in relation to depression: a systematic critical review. Psychother Psychosom. 2005;74(2):69–80. DOI: 10.1159/000083165. PMID: 15741756.15741756
Stewart, Jesse C., Rollman, Bruce L. Optimizing approaches to addressing depression in cardiac patients: A comment on O’Neil et al. Annals of Behavioral Medicine. 2014;48(2):142–144. DOI: 10.1007/s12160-014-9615-x.24722962
Stiles, SW. Does treating depression after MI prevent future events? Cardiology Review. 2003;20(11):44–47.
Tully, PJ, Baumeister, H. Collaborative care for comorbid depression and coronary heart disease: A systematic review and meta-analysis of randomised controlled trials. BMJ Open. 2015;5(12).
Tully, PJ, Baumeister, H. Collaborative care for the treatment of comorbid depression and coronary heart disease: a systematic review and meta-analysis protocol. Syst Rev. 2014;3:127. DOI: 10.1186/2046-4053-3-127. PMID: 25351999.25351999
Unexpected results from SADHART: in over half of cases depression began long before acute coronary events...Sertraline Antidepressant Heart Attack Randomized Trial (SADHART). Brown University Geriatric Psychopharmacology Update. 2006;10(8):1–7. PMID: 106198805.
van Melle, JP, de Jonge, P, Spijkerman, TA, Tijssen, JG, Ormel, J, van Veldhuisen, DJ, van den Brink, RH, van den Berg, MP. Prognostic association of depression following myocardial infarction with mortality and cardiovascular events: a meta-analysis. Psychosom Med. 2004;66(6):814–22. DOI: 10.1097/01.psy.0000146294.82810.9c. PMID: 15564344.15564344
Whang, W, Burg, MM, Carney, RM, Freedland, KE, Bigger, JT, Catellier, D, Czajkowski, S, Frasure-Smith, N, Haas, DC, Jaffe, AS, Lesperance, F, Medina, V, Duer-Hefele, J, Osorio, GA, Parsons, F, Shapiro, PA, Sheps, DS, Vaccarino, V, Davidson, KW. Design and baseline data from the vanguard of the Comparison of Depression Interventions after Acute Coronary Syndrome (CODIACS) randomized controlled trial. Contemp Clin Trials. 2012;33(5):1003–10. DOI: 10.1016/j.cct.2012.05.005. PMID: 22640924.22640924

## Study population is not adults within 3 months of an ACS event who are being screened or treated for depression

Aghakhani, N, Sharif, F, Khademvatan, K, Rahbar, N, Eghtedar, S, Shojaei Motlagh, V. Patients with myocardial infarction. Iranian Cardiovascular Research Journal. 2011;5(2):66–69.
Aghakhani, N, Sharif, F, Khademvatan, K, Rahbar, N, Eghtedar, S, Shojaei Motlagh, V. The reduction in anxiety and depression by education of patients with myocardial infarction. International Cardiovascular Research Journal. 2011;5(2):66–68.
Annagur, BB, Avci, A, Demir, K, Uygur, OF. Is there any difference between the early age myocardial infarction and late age myocardial infarction in terms of psychiatric morbidity in patients who have survived acute myocardial infarction? Compr Psychiatry. 2015;57:10–5. DOI: 10.1016/j.comppsych.2014.11.001. PMID: 25542816.25542816
Bagherian Sararoudi R, Motmaen M, Maracy MR, . Efficacy of illness perception focused intervention on quality of life, anxiety, and depression in patients with myocardial infarction. Journal of Research in Medical Sciences. 2016;21(9).
Bauer, LK, Caro, MA, Beach, SR, Mastromauro, CA, Lenihan, E, Januzzi, JL, Huffman, JC. Effects of depression and anxiety improvement on adherence to medication and health behaviors in recently hospitalized cardiac patients. Am J Cardiol. 2012;109(9):1266–71. DOI: 10.1016/j.amjcard.2011.12.017. PMID: 22325974.22325974
Bot, M, Carney, RM, Freedland, KE, Rubin, EH, Rich, MW, Steinmeyer, BC, Mann, DL. Inflammation and treatment response to sertraline in patients with coronary heart disease and comorbid major depression. J Psychosom Res. 2011;71(1):13–7. DOI: 10.1016/j.jpsychores.2010.11.006. PMID: 21665007.21665007
Busch AM, Tooley EM, Dunsiger S, . Behavioral activation for smoking cessation and mood management following a cardiac event: results of a pilot randomized controlled trial. BMC Public Health. 2017;17(1):323. PMID: 2841597928415979
Carney, RM, Freedland, KE, Rubin, EH, Rich, MW, Steinmeyer, BC, Harris, WS. Omega-3 augmentation of sertraline in treatment of depression in patients with coronary heart disease: a randomized controlled trial. Jama. 2009;302(15):1651–7. DOI: 10.1001/jama.2009.1487. PMID: 19843899.19843899
Carney, RM, Freedland, KE, Stein, PK, Steinmeyer, BC, Harris, WS, Rubin, EH, Krone, RJ, Rich, MW. Effect of omega-3 fatty acids on heart rate variability in depressed patients with coronary heart disease. Psychosom Med. 2010;72(8):748–54. DOI: 10.1097/PSY.0b013e3181eff148. PMID: 20716712.20716712
Celano, CM, Suarez, L, Mastromauro, C, Januzzi, JL, Huffman, JC. Feasibility and utility of screening for depression and anxiety disorders in patients with cardiovascular disease. Circ Cardiovasc Qual Outcomes. 2013;6(4):498–504. DOI: 10.1161/circoutcomes.111.000049. PMID: 23759474.23759474
Cheung, YK, Chakraborty, B, Davidson, KW. Sequential multiple assignment randomized trial (SMART) with adaptive randomization for quality improvement in depression treatment program. Biometrics. 2015;71(2):450–9. DOI: 10.1111/biom.12258. PMID: 25354029.25354029
Chi, MJ, Yu, E, Liu, WW, Lee, MC, Chung, MH. The bidirectional relationship between myocardial infarction and depressive disorders: a follow-up study. Int J Cardiol. 2014;177(3):854–9. DOI: 10.1016/j.ijcard.2014.10.142. PMID: 25466566.25466566
Chiavarino, C, Cavallero, E, Rabellino, D, Palumbo, L, Bianchino, C, Gaita, F, Bergerone, S, Bara, BG. Mental Fitness for patients with acute coronary syndrome: A randomized clinical trial. Br J Health Psychol. 2016;21(3):584–99. DOI: 10.1111/bjhp.12187. PMID: 26932132.26932132
Claesson, M, Birgander, LS, Lindahl, B, Nasic, S, Astrom, M, Asplund, K, Burell, G. Women’s hearts--stress management for women with ischemic heart disease: explanatory analyses of a randomized controlled trial. J Cardiopulm Rehabil. 2005;25(2):93–102. PMID: 15818198.15818198
Dalal, HM, Evans, PH, Campbell, JL, Taylor, RS, Watt, A, Read, KL, Mourant, AJ, Wingham, J, Thompson, DR, Pereira Gray, DJ. Home-based versus hospital-based rehabilitation after myocardial infarction: A randomized trial with preference arms--Cornwall Heart Attack Rehabilitation Management Study (CHARMS). Int J Cardiol. 2007;119(2):202–11. DOI: 10.1016/j.ijcard.2006.11.018. PMID: 17196274.17196274
de Jonge, P, Honig, A, van Melle, JP, Schene, AH, Kuyper, AM, Tulner, D, Schins, A, Ormel, J. Nonresponse to treatment for depression following myocardial infarction: association with subsequent cardiac events. Am J Psychiatry. 2007;164(9):1371–8. DOI: 10.1176/appi.ajp.2007.06091492. PMID: 17728422.17728422
De Smedt, D, Clays, E, Doyle, F, Kotseva, K, Prugger, C, Pajak, A, Jennings, C, Wood, D, De Bacquer, D. Validity and reliability of three commonly used quality of life measures in a large European population of coronary heart disease patients. Int J Cardiol. 2013;167(5):2294–9. DOI: 10.1016/j.ijcard.2012.06.025. PMID: 22748284.22748284
Dickens, C, McGowan, L, Percival, C, Tomenson, B, Cotter, L, Heagerty, A, Creed, F. Negative illness perceptions are associated with new-onset depression following myocardial infarction. Gen Hosp Psychiatry. 2008;30(5):414–20. DOI: 10.1016/j.genhosppsych.2008.04.003. PMID: 18774424.18774424
Esler, D, Johnston, F, Thomas, D, Davis, B. The validity of a depression screening tool modified for use with Aboriginal and Torres Strait Islander people. Aust N Z J Public Health. 2008;32(4):317–21. DOI: 10.1111/j.1753-6405.2008.00247.x. PMID: 18782392.18782392
Freedland, KE, Skala, JA, Carney, RM, Rubin, EH, Lustman, PJ, Davila-Roman, VG, Steinmeyer, BC, Hogue, CW, Jr. Treatment of depression after coronary artery bypass surgery: a randomized controlled trial. Arch Gen Psychiatry. 2009;66(4):387–96. DOI: 10.1001/archgenpsychiatry.2009.7. PMID: 19349308.19349308
Gallagher, R, McKinley, S, Dracup, K. Effects of a telephone counseling intervention on psychosocial adjustment in women following a cardiac event. Heart Lung. 2003;32(2):79–87. DOI: 10.1067/mhl.2003.19. PMID: 12734530.12734530
Gary, RA, Dunbar, SB, Higgins, MK, Musselman, DL, Smith, AL. Combined exercise and cognitive behavioral therapy improves outcomes in patients with heart failure. J Psychosom Res. 2010;69(2):119–31. DOI: 10.1016/j.jpsychores.2010.01.013. PMID: 20624510.20624510
Giallauria, F, Lucci, R, Pilerci, F, De Lorenzo, A, Manakos, A, Psaroudaki, M, Dagostino, M, Vitelli, A, Maresca, L, Del Forno, D, Vigorito, C. Efficacy of telecardiology in improving the results of cardiac rehabilitation after acute myocardial infarction. Monaldi Arch Chest Dis. 2006;66(1):8–12. DOI: 10.4081/monaldi.2006.536. PMID: 17125041.17125041
Giltay, EJ, Geleijnse, JM, Kromhout, D. Effects of n-3 fatty acids on depressive symptoms and dispositional optimism after myocardial infarction. Am J Clin Nutr. 2011;94(6):1442–50. DOI: 10.3945/ajcn.111.018259. PMID: 22030221.22030221
Goh, AC, Wong, S, Zaroff, JG, Shafaee, N, Lundstrom, RJ. Comparing Anxiety and Depression in Patients With Takotsubo Stress Cardiomyopathy to Those With Acute Coronary Syndrome. J Cardiopulm Rehabil Prev. 2016;36(2):106–11. DOI: 10.1097/hcr.0000000000000152. PMID: 26468629.26468629
Haberka, M, Mizia-Stec, K, Mizia, M, Gieszczyk, K, Chmiel, A, Sitnik-Warchulska, K, Gasior, Z. Effects of n-3 polyunsaturated fatty acids on depressive symptoms, anxiety and emotional state in patients with acute myocardial infarction. Pharmacol Rep. 2013;65(1):59–68. PMID: 23563024.23563024
Habra, ME, Baker, B, Frasure-Smith, N, Swenson, JR, Koszycki, D, Butler, G, van Zyl, LT, Lesperance, F. First episode of major depressive disorder and vascular factors in coronary artery disease patients: Baseline characteristics and response to antidepressant treatment in the CREATE trial. J Psychosom Res. 2010;69(2):133–41. DOI: 10.1016/j.jpsychores.2010.02.010. PMID: 20624511.20624511
Hanash, JA, Hansen, BH, Hansen, JF, Nielsen, OW, Rasmussen, A, Birket-Smith, M. Cardiovascular safety of one-year escitalopram therapy in clinically nondepressed patients with acute coronary syndrome: results from the DEpression in patients with Coronary ARtery Disease (DECARD) trial. J Cardiovasc Pharmacol. 2012;60(4):397–405. DOI: 10.1097/FJC.0b013e3182677041. PMID: 22820898.22820898
Hansen, BH, Hanash, JA, Rasmussen, A, Hansen, JF, Birket-Smith, M. Rationale, design and methodology of a double-blind, randomized, placebo-controlled study of escitalopram in prevention of Depression in Acute Coronary Syndrome (DECARD). Trials. 2009;10:20. DOI: 10.1186/1745-6215-10-20. PMID: 19351383.19351383
Huffman, JC, Mastromauro, CA, Beach, SR, Celano, CM, DuBois, CM, Healy, BC, Suarez, L, Rollman, BL, Januzzi, JL. Collaborative care for depression and anxiety disorders in patients with recent cardiac events: the Management of Sadness and Anxiety in Cardiology (MOSAIC) randomized clinical trial. JAMA Intern Med. 2014;174(6):927–35. DOI: 10.1001/jamainternmed.2014.739. PMID: 24733277.24733277
Huffman, JC, Mastromauro, CA, Boehm, JK, Seabrook, R, Fricchione, GL, Denninger, JW, Lyubomirsky, S. Development of a positive psychology intervention for patients with acute cardiovascular disease. Heart International. 2011;6(2):47–54.
Huffman, JC, Mastromauro, CA, Sowden, G, Fricchione, GL, Healy, BC, Januzzi, JL. Impact of a depression care management program for hospitalized cardiac patients. Circ Cardiovasc Qual Outcomes. 2011;4(2):198–205. DOI: 10.1161/circoutcomes.110.959379. PMID: 21386067.21386067
Huffman, JC, Smith, FA, Blais, MA, Januzzi, JL, Fricchione, GL. Anxiety, independent of depressive symptoms, is associated with in-hospital cardiac complications after acute myocardial infarction. J Psychosom Res. 2008;65(6):557–63. DOI: 10.1016/j.jpsychores.2008.08.001. PMID: 19027445.19027445
Hunger, M, Kirchberger, I, Holle, R, Seidl, H, Kuch, B, Wende, R, Meisinger, C. Does nurse-based case management for aged myocardial infarction patients improve risk factors, physical functioning and mental health? The KORINNA trial. Eur J Prev Cardiol. 2015;22(4):442–50. DOI: 10.1177/2047487314524682. PMID: 24523431.24523431
Iles-Smith, H, McGowan, L, Campbell, M, Mercer, C, Deaton, C. A prospective cohort study investigating readmission, symptom attribution and psychological health within six months of primary percutaneous coronary intervention. Eur J Cardiovasc Nurs. 2015;14(6):506–15. DOI: 10.1177/1474515114543227. PMID: 25022832.25022832
Jiang, W, O’Connor, C, Silva, SG, Kuchibhatla, M, Cuffe, MS, Callwood, DD, Zakhary, B, Henke, E, Arias, RM, Krishnan, R. Safety and efficacy of sertraline for depression in patients with CHF (SADHART-CHF): a randomized, double-blind, placebo-controlled trial of sertraline for major depression with congestive heart failure. Am Heart J. 2008;156(3):437–44. DOI: 10.1016/j.ahj.2008.05.003. PMID: 18760123.18760123
Jolly, K, Lip, GY, Taylor, RS, Raftery, J, Mant, J, Lane, D, Greenfield, S, Stevens, A. The Birmingham Rehabilitation Uptake Maximisation study (BRUM): a randomised controlled trial comparing home-based with centre-based cardiac rehabilitation. Heart. 2009;95(1):36–42. DOI: 10.1136/hrt.2007.127209. PMID: 18332063.18332063
Jolly, K, Taylor, RS, Lip, GY, Davies, M, Davis, R, Mant, J, Singh, S, Greenfield, S, Ingram, J, Stubley, J, Bryan, S, Stevens, A. A randomized trial of the addition of home-based exercise to specialist heart failure nurse care: the Birmingham Rehabilitation Uptake Maximisation study for patients with Congestive Heart Failure (BRUM-CHF) study. Eur J Heart Fail. 2009;11(2):205–13. DOI: 10.1093/eurjhf/hfn029. PMID: 19168520.19168520
Jolly, K, Taylor, R, Lip, GY, Greenfield, S, Raftery, J, Mant, J, Lane, D, Jones, M, Lee, KW, Stevens, A. The Birmingham Rehabilitation Uptake Maximisation Study (BRUM). Home-based compared with hospital-based cardiac rehabilitation in a multi-ethnic population: cost-effectiveness and patient adherence. Health Technol Assess. 2007;11(35):1–118. PMID: 17767899.17767899
Jorstad HT, von Birgelen C, Alings AM, . Effect of a nurse-coordinated prevention programme on cardiovascular risk after an acute coronary syndrome: main results of the RESPONSE randomised trial. Heart. 2013;99(19):1421–30. PMID: 23813851.23813851
Jorstad, HT, Minneboo, M, Helmes, HJ, Fagel, ND, Scholte Op Reimer, WJ, Tijssen, JG, Peters, RJ. Effects of a nurse-coordinated prevention programme on health-related quality of life and depression in patients with an acute coronary syndrome: results from the RESPONSE randomised controlled trial. BMC Cardiovasc Disord. 2016;16(1):144. DOI: 10.1186/s12872-016-0321-4. PMID: 27391321.27391321
Kala, P, Hudakova, N, Jurajda, M, Kasparek, T, Ustohal, L, Parenica, J, Sebo, M, Holicka, M, Kanovsky, J. Depression and Anxiety after Acute Myocardial Infarction Treated by Primary PCI. PLoS One. 2016;11(4):e0152367. DOI: 10.1371/journal.pone.0152367. PMID: 27074002.27074002
Kang, L, Zhang, SY, Zhu, WL, Pang, HY, Zhang, L, Zhu, ML, Liu, XH, Liu, YT. Is frailty associated with short-term outcomes for elderly patients with acute coronary syndrome?. J Geriatr Cardiol. 2015;12(6):662–7. DOI: 10.11909/j.issn.1671-5411.2015.06.010. PMID: 26788044.26788044
Keegan, C, Conroy, R, Doyle, F. Longitudinal modelling of theory-based depressive vulnerabilities, depression trajectories and poor outcomes post-ACS. J Affect Disord. 2016;191:41–8. DOI: 10.1016/j.jad.2015.11.030. PMID: 26650967.26650967
Koertge, J, Janszky, I, Sundin, O, Blom, M, Georgiades, A, Laszlo, KD, Alinaghizadeh, H, Ahnve, S. Effects of a stress management program on vital exhaustion and depression in women with coronary heart disease: a randomized controlled intervention study. J Intern Med. 2008;263(3):281–93. DOI: 10.1111/j.1365-2796.2007.01887.x. PMID: 18067552.18067552
Korzeniowska-Kubacka I, Bilinska M, Piotrowska D, . The impact of exercise-only-based rehabilitation on depression and anxiety in patients after myocardial infarction. Eur J Cardiovasc Nurs. 2016. PMID: 27899438.27899438
Kraglund, KL, Mortensen, JK, Grove, EL, Johnsen, SP, Andersen, G. TALOS: a multicenter, randomized, double-blind, placebo-controlled trial to test the effects of citalopram in patients with acute stroke. Int J Stroke. 2015;10(6):985–7. DOI: 10.1111/ijs.12485. PMID: 25854537.25854537
Langvik, E, Hjemdal, O. Symptoms of depression and anxiety before and after myocardial infarction: The HUNT 2 and HUNT 3 study. Psychol Health Med. 2015;20(5):560–9. DOI: 10.1080/13548506.2014.989864. PMID: 25495669.25495669
Larsen, KK. Depression following myocardial infarction--an overseen complication with prognostic importance. Dan Med J. 2013;60(8):B4689. PMID: 23905572.23905572
Le Grande, MR, Murphy, BM, Rogerson, MC, Elliott, PC, Worcester, MUC. Determinants of physical activity guideline attainment in Australian Cardiac Patients: A 12-Month Study. Journal of Cardiopulmonary Rehabilitation and Prevention. 2015;35(6):399–408.26378492
Lesperance, F, Frasure-Smith, N, Koszycki, D, Laliberte, MA, van Zyl, LT, Baker, B, Swenson, JR, Ghatavi, K, Abramson, BL, Dorian, P, Guertin, MC. Effects of citalopram and interpersonal psychotherapy on depression in patients with coronary artery disease: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy (CREATE) trial. Jama. 2007;297(4):367–79. DOI: 10.1001/jama.297.4.367. PMID: 17244833.17244833
Lilja, G, Nilsson, G, Nielsen, N, Friberg, H, Hassager, C, Koopmans, M, Kuiper, M, Martini, A, Mellinghoff, J, Pelosi, P, Wanscher, M, Wise, MP, Ostman, I, Cronberg, T. Anxiety and depression among out-of-hospital cardiac arrest survivors. Resuscitation. 2015;97:68–75. DOI: 10.1016/j.resuscitation.2015.09.389. PMID: 26433116.26433116
Lounsbury, P, Elokda, AS, Sitzmann, J, Li, Q. Efficacy of external counterpulsation enhanced with outpatient cardiac rehabilitation. European Journal of Physiotherapy. 2016;18(1):27–33.
McManus, D, Pipkin, SS, Whooley, MA. Screening for depression in patients with coronary heart disease (data from the Heart and Soul Study). Am J Cardiol. 2005;96(8):1076–81. DOI: 10.1016/j.amjcard.2005.06.037. PMID: 16214441.16214441
Meiyan, L, Yanping, R, Chengjun, G. The changes of depressive and anxious status following acute myocardial infarction. Experimental and Clinical Cardiology. 2014;20(8):2886–2904.
Milani, RV, Lavie, CJ. Impact of cardiac rehabilitation on depression and its associated mortality. Am J Med. 2007;120(9):799–806. DOI: 10.1016/j.amjmed.2007.03.026. PMID: 17765050.17765050
Mitchell, PH, Powell, L, Blumenthal, J, Norten, J, Ironson, G, Pitula, CR, Froelicher, ES, Czajkowski, S, Youngblood, M, Huber, M, Berkman, LF. A short social support measure for patients recovering from myocardial infarction: the ENRICHD Social Support Inventory. J Cardiopulm Rehabil. 2003;23(6):398–403. PMID: 14646785.14646785
Murphy, B, Ludeman, D, Elliott, P, Judd, F, Humphreys, J, Edington, J, Jackson, A, Worcester, M. Red flags for persistent or worsening anxiety and depression after an acute cardiac event: a 6-month longitudinal study in regional and rural Australia. Eur J Prev Cardiol. 2014;21(9):1079–89. DOI: 10.1177/2047487313493058. PMID: 23733741.23733741
Niakan, M, Paryad, E, Kazemnezhad Leili, E, Sheikholeslami, F. Depressive symptoms effect on self care behavior during the first month after myocardial infarction. Glob J Health Sci. 2015;7(4):382–91. DOI: 10.5539/gjhs.v7n4p382. PMID: 25946944.25946944
Norlund, F., Olsson, E. M. G., Pingel, R., Held, C., Svärdsudd, K., Gulliksson, M., Burell,G. Psychological mediators related to clinical outcome in cognitive behavioural therapy for coronary heart disease: A sub-analysis from the SUPRIM trial. European Journal of Preventive Cardiology. 2017;24(9):917–925. DOI: 10.1177/2047487317693131.28195501
Oranta, O, Luutonen, S, Salokangas, RK, Vahlberg, T, Leino-Kilpi, H. Depression-focused interpersonal counseling and the use of healthcare services after myocardial infarction. Perspect Psychiatr Care. 2012;48(1):47–55. DOI: 10.1111/j.1744-6163.2011.00305.x. PMID: 22188047.22188047
Oranta, O, Luutonen, S, Salokangas, RK, Vahlberg, T, Leino-Kilpi, H. The outcomes of interpersonal counselling on depressive symptoms and distress after myocardial infarction. Nord J Psychiatry. 2010;64(2):78–86. DOI: 10.3109/08039480903402227. PMID: 19919291.19919291
Ossola, P, Paglia, F, Pelosi, A, De Panfilis, C, Conte, G, Tonna, M, Ardissino, D, Marchesi, C. Risk factors for incident depression in patients at first acute coronary syndrome. Psychiatry Res. 2015;228(3):448–53. DOI: 10.1016/j.psychres.2015.05.063. PMID: 26144582.26144582
Pourafkari, L, Ghaffari, S, Shahamfar, J, Tokhmechian, L, Nader, ND. The psychological effects of cardiac rehabilitation after coronary revascularization. Turk Kardiyoloji Dernegi Arsivi. 2016;44(3):228–236.27138312
Roest, AM, Wardenaar, KJ, de Jonge, P. Symptom and course heterogeneity of depressive symptoms and prognosis following myocardial infarction. Health Psychol. 2016;35(5):413–22. DOI: 10.1037/hea0000256. PMID: 26389721.26389721
Roncella, A, Giornetti, A, Cianfrocca, C, Pasceri, V, Pelliccia, F, Denollet, J, Pedersen, SS, Speciale, G, Richichi, G, Pristipino, C. Rationale and trial design of a randomized, controlled study on short-term psychotherapy after acute myocardial infarction: the STEP-IN-AMI trial (Short Term Psychotherapy in Acute Myocardial Infarction). J Cardiovasc Med (Hagerstown). 2009;10(12):947–452. DOI: 10.2459/JCM.0b013e32832fb477. PMID: 19623081.19623081
Roncella, A, Pristipino, C, Cianfrocca, C, Scorza, S, Pasceri, V, Pelliccia, F, Denollet, J, Pedersen, SS, Speciale, G. One-year results of the randomized, controlled, short-term psychotherapy in acute myocardial infarction (STEP-IN-AMI) trial. Int J Cardiol. 2013;170(2):132–9. DOI: 10.1016/j.ijcard.2013.08.094. PMID: 24239154.24239154
Rutledge, T, Kenkre, TS, Thompson, DV, Bittner, VA, Whittaker, K, Eastwood, JA, Eteiba, W, Cornell, CE, Krantz, DS, Pepine, CJ, Johnson, BD, Handberg, EM, Bairey Merz, CN. Depression, dietary habits, and cardiovascular events among women with suspected myocardial ischemia. Am J Med. 2014;127(9):840–7. DOI: 10.1016/j.amjmed.2014.04.011. PMID: 24769297.24769297
Salminen, M, Isoaho, R, Vahlberg, T, Ojanlatva, A, Kivela, SL. Effects of a health advocacy, counselling, and activation programme on depressive symptoms in older coronary heart disease patients. Int J Geriatr Psychiatry. 2005;20(6):552–8. DOI: 10.1002/gps.1323. PMID: 15920714.15920714
Ski, CF, Page, K, Thompson, DR, Cummins, RA, Salzberg, M, Worrall-Carter, L. Clinical outcomes associated with screening and referral for depression in an acute cardiac ward. J Clin Nurs. 2012;21(15–16):2228–34. DOI: 10.1111/j.1365-2702.2011.03934.x. PMID: 22268823.22268823
Stafford, L, Berk, M, Jackson, HJ. Validity of the Hospital Anxiety and Depression Scale and Patient Health Questionnaire-9 to screen for depression in patients with coronary artery disease. Gen Hosp Psychiatry. 2007;29(5):417–24. DOI: 10.1016/j.genhosppsych.2007.06.005. PMID: 17888808.17888808
Stenman, M, Holzmann, MJ, Sartipy, U. Relation of major depression to survival after coronary artery bypass grafting. Am J Cardiol. 2014;114(5):698–703. DOI: 10.1016/j.amjcard.2014.05.058. PMID: 25027773.25027773
Stetkiewicz-Lewandowicz, A, Borkowska, A, Sobów, T. Depressive symptoms and working memory dysfunctions in patients with ischemic heart disease. Acta Neuropsychologica. 2015;13(2):145–155.
Sundin, O, Lisspers, J, Hofman-Bang, C, Nygren, A, Ryden, L, Ohman, A. Comparing multifactorial lifestyle interventions and stress management in coronary risk reduction. Int J Behav Med. 2003;10(3):191–204. PMID: 14525716.14525716
Thomas, SA, Friedmann, E, Lee, HJ, Son, H, Morton, PG. Changes in anxiety and depression over 2 years in medically stable patients after myocardial infarction and their spouses in the Home Automatic External Defibrillator Trial (HAT): a longitudinal observational study. Heart. 2011;97(5):371–81. DOI: 10.1136/hrt.2009.184119. PMID: 20930046.20930046
Thombs, BD, Ziegelstein, RC, Whooley, MA. Optimizing detection of major depression among patients with coronary artery disease using the patient health questionnaire: data from the heart and soul study. J Gen Intern Med. 2008;23(12):2014–7. DOI: 10.1007/s11606-008-0802-y. PMID: 18815842.18815842
Tisminetzky, M, Bray, BC, Miozzo, R, Aupont, O, McLaughlin, T. Classes of depression, anxiety, and functioning in acute coronary syndrome patients. Am J Health Behav. 2012;36(1):20–30. PMID: 22251780.22251780
Tylee, A, Barley, EA, Walters, P, Achilla, E, Borschmann, R, Leese, M, McCrone, P, Palacios, J, Smith, A, Simmonds, R, Rose, D, Murray, J, van Marwijk, H, Williams, P, Mann, A, on behalf of the, Upbeat- U. K. team. Programme Grants for Applied Research. UPBEAT-UK: a programme of research into the relationship between coronary heart disease and depression in primary care patients. 2016. DOI: 10.3310/pgfar04080. PMID: 27253001.27253001
Wang W, Jiang Y, He HG, . A randomised controlled trial on the effectiveness of a home-based self-management programme for community-dwelling patients with myocardial infarction. European Journal of Cardiovascular Nursing. 2016;15(6):398–408.25952055
Warber, SL, Ingerman, S, Moura, VL, Wunder, J, Northrop, A, Gillespie, BW, Durda, K, Smith, K, Rhodes, KS, Rubenfire, M. Healing the heart: a randomized pilot study of a spiritual retreat for depression in acute coronary syndrome patients. Explore (NY). 2011;7(4):222–33. DOI: 10.1016/j.explore.2011.04.002. PMID: 21724155.21724155
Weibel, L, Massarotto, P, Hediger, H, Mahrer-Imhof, R. Early education and counselling of patients with acute coronary syndrome. A pilot study for a randomized controlled trial. Eur J Cardiovasc Nurs. 2016;15(4):213–22. DOI: 10.1177/1474515114556713. PMID: 25341680.25341680
Wheeler, A, Schrader, G, Tucker, G, Adams, R, Tavella, R, Beltrame, JF. Prevalence of depression in patients with chest pain and non-obstructive coronary artery disease. Am J Cardiol. 2013;112(5):656–9. DOI: 10.1016/j.amjcard.2013.04.042. PMID: 23711812.23711812
Wilkowska, A, Pikula, M, Rynkiewicz, A, Wdowczyk-Szulc, J, Trzonkowski, P, Landowski, J. Increased plasma pro-inflammatory cytokine concentrations after myocardial infarction and the presence of depression during next 6-months. Psychiatr Pol. 2015;49(3):455–64. DOI: 10.12740/pp/33179. PMID: 26276914.26276914
Yesilbursa, D, Aydinlar, A, Karaagac, K, Ucar, H, Akturk, Y, Yetgin, ZA. The comparison of depression and anxiety levels in patients with acute coronary syndrome. Journal of Clinical and Analytical Medicine. 2014;5(5):390–393.
Zimmer, R, Riemer, T, Rauch, B, Schneider, S, Schiele, R, Gohlke, H, Diller, F, Steinbeck, G, Katus, H, Senges, J. Effects of 1-year treatment with highly purified omega-3 fatty acids on depression after myocardial infarction: results from the OMEGA trial. J Clin Psychiatry. 2013;74(11):e1037–45. DOI: 10.4088/JCP.13m08453. PMID: 24330904.24330904
Zuidersma, M, Conradi, HJ, van Melle, JP, Ormel, J, de Jonge, P. Self-reported depressive symptoms, diagnosed clinical depression and cardiac morbidity and mortality after myocardial infarction. Int J Cardiol. 2013;167(6):2775–80. DOI: 10.1016/j.ijcard.2012.07.002. PMID: 22835990.22835990

## Does not meet study design or sample size requirements

Aghakhani, N, Khademvatan, K, Dehghani, MR. The effect of written material and verbal method education on anxiety and depression in patients with myocardial infarction in selected hospitals in Iran. J Adv Med Educ Prof. 2014;2(4):165–9. PMID: 25512941.25512941
Blumenthal, JA, Babyak, MA, Carney, RM, Huber, M, Saab, PG, Burg, MM, Sheps, D, Powell, L, Taylor, CB, Kaufmann, PG. Exercise, depression, and mortality after myocardial infarction in the ENRICHD trial. Med Sci Sports Exerc. 2004;36(5):746–55. PMID: 15126705.15126705
Delisle, VC, Arthurs, E, Abbey, SE, Grace, SL, Stewart, DE, Steele, RJ, Ziegelstein, RC, Thombs, BD. Symptom reporting on the Beck Depression Inventory among post-myocardial infarction patients: in-hospital versus follow-up assessments. J Psychosom Res. 2012;73(5):356–61. DOI: 10.1016/j.jpsychores.2012.08.021. PMID: 23062809.23062809
Denton, EG, Shaffer, JA, Alcantara, C, Cadermil, E. Neighborhood matters: the impact of Hispanic ethnic density on future depressive symptoms 1-year following an ACS event among Hispanic patients. J Behav Med. 2016;39(1):28–40. DOI: 10.1007/s10865-015-9679-5. PMID: 26407692.26407692
DiSante JL, Bires AM, Cline TW, . An Analysis of the Prevalence of Depression Post-Myocardial Infarction. Crit Care Nurs Q. 2017;40(2):124–136. PMID: 28240695.28240695
Hansen, VB, Maindal, HT. Cardiac rehabilitation with a nurse case manager (GoHeart) across local and regional health authorities improves risk factors, self-care and psychosocial outcomes. A one-year follow-up study. JRSM Cardiovasc Dis. 2014;3:2048004014555922. DOI: 10.1177/2048004014555922. PMID: 25396055.25396055
Heeres RHM, Hoogeveen EK, Geleijnse JM, . Kidney dysfunction, systemic inflammation and mental well-being in elderly post-myocardial infarction patients. BMC Psychology. 2017;5.
Huffman JC, Millstein RA, Mastromauro CA, . A Positive Psychology Intervention for Patients with an Acute Coronary Syndrome: Treatment Development and Proof-of-Concept Trial. J Happiness Stud. 2016;17(5):1985–2006. PMID: 28082831.28082831
Jani, BD, Cavanagh, J, Barry, SJ, Der, G, Sattar, N, Mair, FS. Relationship Between Blood Pressure Values, Depressive Symptoms, and Cardiovascular Outcomes in Patients With Cardiometabolic Disease. J Clin Hypertens (Greenwich). 2016. DOI: 10.1111/jch.12813. PMID: 27040355.27040355
Ladapo, Joseph A, Shaffer, Jonathan A, Fang, Yixin, Ye, Siqin, Davidson, Karina W. Cost-effectiveness of enhanced depression care after acute coronary syndrome: results from the Coronary Psychosocial Evaluation Studies randomized controlled trial. Archives of Internal Medicine. 2012;172(21):1682–1684. PMID: 108001662.23070196
Larsen, KK, Christensen, B, Sondergaard, J, Vestergaard, M. Depressive symptoms and risk of new cardiovascular events or death in patients with myocardial infarction: a population-based longitudinal study examining health behaviors and health care interventions. PLoS One. 2013;8(9):e74393. DOI: 10.1371/journal.pone.0074393. PMID: 24086339.24086339
Meurs, M, Burger, H, van Riezen, J, Slaets, JP, Rosmalen, JG, van Melle, JP, Roest, AM, de Jonge, P. The association between cardiac rehabilitation and mortality risk for myocardial infarction patients with and without depressive symptoms. J Affect Disord. 2015;188:278–83. DOI: 10.1016/j.jad.2015.08.057. PMID: 26384014.26384014
Rieckmann, N, Kronish, IM, Shapiro, PA, Whang, W, Davidson, KW. Serotonin reuptake inhibitor use, depression, and long-term outcomes after an acute coronary syndrome: a prospective cohort study. JAMA Intern Med. 2013;173(12):1150–1. DOI: 10.1001/jamainternmed.2013.910. PMID: 23699784.23699784
Smolderen KG, Spertus JA, Gosch K, . Depression Treatment and Health Status Outcomes in Young Patients With Acute Myocardial Infarction: Insights From the VIRGO Study (Variation in Recovery: Role of Gender on Outcomes of Young AMI Patients). Circulation. 2017;135:1762–1764.28461419
Smolderen KG, Buchanan DM, Gosch K, . Depression Treatment and 1-Year Mortality Following Acute Myocardial Infarction: Insights from the TRIUMPH Registry. Circulation. 2017. PMID: 28209727.28209727
Taylor, CB, Youngblood, ME, Catellier, D, Veith, RC, Carney, RM, Burg, MM, Kaufmann, PG, Shuster, J, Mellman, T, Blumenthal, JA, Krishnan, R, Jaffe, AS. Effects of antidepressant medication on morbidity and mortality in depressed patients after myocardial infarction. Arch Gen Psychiatry. 2005;62(7):792–8. DOI: 10.1001/archpsyc.62.7.792. PMID: 15997021.15997021

## No eligible intervention

Behnammoghadam, M, Alamdari, AK, Behnammoghadam, A, Darban, F. Effect of Eye Movement Desensitization and Reprocessing (EMDR) on Depression in Patients With Myocardial Infarction (MI). Glob J Health Sci. 2015;7(6):258–62. DOI: 10.5539/gjhs.v7n6p258. PMID: 26153191.26153191
Bunevicius, A, Staniute, M, Brozaitiene, J, Pommer, AM, Pop, VJ, Montgomery, SA, Bunevicius, R. Evaluation of depressive symptoms in patients with coronary artery disease using the Montgomery Asberg Depression Rating Scale. Int Clin Psychopharmacol. 2012;27(5):249–55. DOI: 10.1097/YIC.0b013e328357670d. PMID: 22869009.22869009
Freedland, KE, Carney, RM, Hayano, J, Steinmeyer, BC, Reese, RL, Roest, AM. Effect of obstructive sleep apnea on response to cognitive behavior therapy for depression after an acute myocardial infarction. J Psychosom Res. 2012;72(4):276–81. DOI: 10.1016/j.jpsychores.2011.12.012. PMID: 22405221.22405221
Lett, HS, Blumenthal, JA, Babyak, MA, Catellier, DJ, Carney, RM, Berkman, L. F., Burg, M. M., Mitchell, P., Jaffe, A. S., Schneiderman, N.. Social support and prognosis in patients at increased psychosocial risk recovering from myocardial infarction. Health Psychol. 2007;26(4):418–27. DOI: 10.1037/0278-6133.26.4.418. PMID: 17605561.17605561
Reese, RL, Freedland, KE, Steinmeyer, BC, Rich, MW, Rackley, JW, Carney, RM. Depression and rehospitalization following acute myocardial infarction. Circ Cardiovasc Qual Outcomes. 2011;4(6):626–33. DOI: 10.1161/circoutcomes.111.961896. PMID: 22010201.22010201
Ziegelstein, Roy C, Kim, So Young, Kao, David, Fauerbach, James A, Thombs, Brett D, McCann, Una, Colburn, Jessica, Bush, David E. Can Doctors and Nurses Recognize Depression in Patients Hospitalized With an Acute Myocardial Infarction in the Absence of Formal Screening?. Psychosomatic Medicine. 2005;67(3):393–397. DOI: 10.1097/01.psy.0000160475.38930.8d.15911901

## No comparator of interest

Blumenthal, JA, Babyak, MA, Ironson, G, Thoresen, C, Powell, L, Czajkowski, S, Burg, M, Keefe, FJ, Steffen, P, Catellier, D. Spirituality, religion, and clinical outcomes in patients recovering from an acute myocardial infarction. Psychosom Med. 2007;69(6):501–8. DOI: 10.1097/PSY.0b013e3180cab76c. PMID: 17636153.17636153
Frazier, Lorraine, Sanner, Jennifer, Yu, Erica, Cron, Stanley G, Moeller, F. Gerard. Using a single screening question for depressive symptoms in patients with acute coronary syndrome. Journal of Cardiovascular Nursing. 2014;29(4):347–353. DOI: 10.1097/JCN.0b013e318291ee16. PMID: 2014-24642-003.23635808
Glassman, AH, Bigger, JT, Jr, Gaffney, M. Psychiatric characteristics associated with long-term mortality among 361 patients having an acute coronary syndrome and major depression: seven-year follow-up of SADHART participants. Arch Gen Psychiatry. 2009;66(9):1022–9. DOI: 10.1001/archgenpsychiatry.2009.121. PMID: 19736359.19736359
Glassman, AH, Bigger, JT, Gaffney, M, Shapiro, PA, Swenson, JR. Onset of major depression associated with acute coronary syndromes: relationship of onset, major depressive disorder history, and episode severity to sertraline benefit. Arch Gen Psychiatry. 2006;63(3):283–8. DOI: 10.1001/archpsyc.63.3.283. PMID: 16520433.16520433
Honig, A, Kuyper, AM, Schene, AH, van Melle, JP, de Jonge, P, Tulner, DM, Schins, A, Crijns, HJ, Kuijpers, PM, Vossen, H, Lousberg, R, Ormel, J. Treatment of post-myocardial infarction depressive disorder: a randomized, placebo-controlled trial with mirtazapine. Psychosom Med. 2007;69(7):606–13. DOI: 10.1097/PSY.0b013e31814b260d. PMID: 17846258.17846258
Lattanzio, F, Cherubini, A, Furneri, G, Di Bari, M, Marchionni, N. Sertraline treatment for depression associated with acute coronary syndromes: a cost analysis from the viewpoint of the Italian Healthcare System. Aging Clin Exp Res. 2008;20(1):76–80. PMID: 18283232.18283232
Martin, CR, Lewin, RJ, Thompson, DR. A confirmatory factor analysis of the Hospital Anxiety and Depression Scale in coronary care patients following acute myocardial infarction. Psychiatry Res. 2003;120(1):85–94. PMID: 14500117.14500117
O’Connor, CM, Glassman, AH, Harrison, DJ. Pharmacoeconomic analysis of sertraline treatment of depression in patients with unstable angina or a recent myocardial infarction. J Clin Psychiatry. 2005;66(3):346–52. PMID: 15766301.15766301
Smolderen, KG, Buchanan, DM, Amin, AA, Gosch, K, Nugent, K, Riggs, L, Seavey, G, Spertus, JA. Real-world lessons from the implementation of a depression screening protocol in acute myocardial infarction patients: implications for the American Heart Association depression screening advisory. Circ Cardiovasc Qual Outcomes. 2011;4(3):283–92. DOI: 10.1161/circoutcomes.110.960013. PMID: 21505152.21505152
Suarez, L, Beach, SR, Moore, SV, Mastromauro, CA, Januzzi, JL, Celano, CM, Chang, TE, Huffman, JC. Use of the Patient Health Questionnaire-9 and a Detailed Suicide Evaluation in Determining Imminent Suicidality in Distressed Patients With Cardiac Disease. Psychosomatics. 2015;56(2):181–189.25660436
Swenson, JR, O’Connor, CM, Barton, D, Van Zyl, LT, Swedberg, K, Forman, LM, Gaffney, M, Glassman, AH. Influence of depression and effect of treatment with sertraline on quality of life after hospitalization for acute coronary syndrome. Am J Cardiol. 2003;92(11):1271–6. PMID: 14636902.14636902
Tesio, V, Marra, S, Molinaro, S, Torta, R, Gaita, F, Castelli, L.. Screening of depression in cardiology: A study on 617 cardiovascular patients. International Journal of Cardiology. 2017. DOI: 10.1016/j.ijcard.2017.07.065.

## No outcomes of interest

Bradt, J, Dileo, C, Potvin, N. Music for stress and anxiety reduction in coronary heart disease patients. Cochrane Database Syst Rev. 2013;(12):Cd006577. DOI: 10.1002/14651858.CD006577.pub3. PMID: 24374731.24374731
Denollet, J, de Jonge, P, Kuyper, A, Schene, AH, van Melle, JP, Ormel, J, Honig, A. Depression and Type D personality represent different forms of distress in the Myocardial INfarction and Depression - Intervention Trial (MIND-IT). Psychol Med. 2009;39(5):749–56. DOI: 10.1017/s0033291708004157. PMID: 18694538.18694538
Glassman, AH, Bigger, JT, Gaffney, M, Van Zyl, LT. Heart rate variability in acute coronary syndrome patients with major depression: influence of sertraline and mood improvement. Arch Gen Psychiatry. 2007;64(9):1025–31. DOI: 10.1001/archpsyc.64.9.1025. PMID: 17768267.17768267
Kang, H. J., Bae, K. Y., Kim, S. W., Shin, I. S., Hong, Y. J., Ahn, Y., Jeong, M. H., Yoon, J. S., Kim, J. M.. Effects of Escitalopram on Anxiety in Patients with Acute Coronary Syndrome: A Randomized Controlled Trial. Clin Psychopharmacol Neurosci. 2017;15(2):126–131. DOI: 10.9758/cpn.2017.15.2.126. PMID: 28449559.28449559
Martens, EJ, Denollet, J, Pedersen, SS, Scherders, M, Griez, E, Widdershoven, J, Szabo, B, Bonnier, H, Appels, A. Relative lack of depressive cognitions in post-myocardial infarction depression. J Affect Disord. 2006;94(1–3):231–7. DOI: 10.1016/j.jad.2006.04.023. PMID: 16733070.16733070
O’Neil, A, Hawkes, AL, Atherton, JJ, Patrao, TA, Sanderson, K, Wolfe, R, Taylor, CB, Oldenburg, B. Telephone-delivered health coaching improves anxiety outcomes after myocardial infarction: the ‘ProActive Heart’ trial. Eur J Prev Cardiol. 2014;21(1):30–8. DOI: 10.1177/2047487312460515. PMID: 22956633.22956633
Serebruany, VL, Glassman, AH, Malinin, AI, Nemeroff, CB, Musselman, DL, van Zyl, LT, Finkel, MS, Krishnan, KR, Gaffney, M, Harrison, W, Califf, RM, O’Connor, CM. Platelet/endothelial biomarkers in depressed patients treated with the selective serotonin reuptake inhibitor sertraline after acute coronary events: the Sertraline AntiDepressant Heart Attack Randomized Trial (SADHART) Platelet Substudy. Circulation. 2003;108(8):939–44. DOI: 10.1161/01.cir.0000085163.21752.0a. PMID: 12912814.12912814
Serebruany, VL, Suckow, RF, Cooper, TB, O’Connor, CM, Malinin, AI, Krishnan, KR, van Zyl, LT, Lekht, V, Glassman, AH. Relationship between release of platelet/endothelial biomarkers and plasma levels of sertraline and N-desmethylsertraline in acute coronary syndrome patients receiving SSRI treatment for depression. Am J Psychiatry. 2005;162(6):1165–70. DOI: 10.1176/appi.ajp.162.6.1165. PMID: 15932816.15932816
Strik, JJ, Honig, A, Klinkenberg, E, Dijkstra, J, Jolles, J. Cognitive performance following fluoxetine treatment in depressed patients post myocardial infarction. Acta Neuropsychiatr. 2006;18(1):1–6. DOI: 10.1111/j.0924-2708.2006.00110.x. PMID: 26991975.26991975
Thombs, BD, Ziegelstein, RC, Beck, CA, Pilote, L. A general factor model for the Beck Depression Inventory-II: validation in a sample of patients hospitalized with acute myocardial infarction. J Psychosom Res. 2008;65(2):115–21. DOI: 10.1016/j.jpsychores.2008.02.027. PMID: 18655855.18655855
Tian X, Wang Q, Guo R, . Effects of paroxetine-mediated inhibition of GRK2 expression on depression and cardiovascular function in patients with myocardial infarction. Neuropsychiatr Dis Treat. 2016;12:2333–2341. PMID: 2769533427695334
Tulner, DM, Smith, OR, Schins, A, de Jonge, P, Quere, M, Delanghe, JR, Crijns, HJ, den Boer, JA, Korf, J, Honig, A. Antidepressive effect of mirtazapine in post-myocardial infarction depression is associated with soluble TNF-R1 increase: data from the MIND-IT. Neuropsychobiology. 2011;63(3):169–76. DOI: 10.1159/000321624. PMID: 21228609.21228609
van Melle, JP, de Jonge, P, Kuyper, AM, Honig, A, Schene, AH, Crijns, HJ, van den Berg, MP, van Veldhuisen, DJ, Ormel, J. Prediction of depressive disorder following myocardial infarction data from the Myocardial INfarction and Depression-Intervention Trial (MIND-IT). Int J Cardiol. 2006;109(1):88–94. DOI: 10.1016/j.ijcard.2005.05.053. PMID: 16002163.16002163

## Treatment study that does not provide at least 6 weeks of follow-up

Barth, J, Paul, J, Harter, M, Bengel, J. Inpatient psychotherapeutic treatment for cardiac patients with depression in Germany - short term results. Psychosoc Med. 2005;2:Doc04. PMID: 19742062.19742062
Huffman, JC, Mastromauro, CA, Sowden, GL, Wittmann, C, Rodman, R, Januzzi, JL. A collaborative care depression management program for cardiac inpatients: depression characteristics and in-hospital outcomes. Psychosomatics. 2011;52(1):26–33. DOI: 10.1016/j.psym.2010.11.021. PMID: 21300192.21300192

## Not a setting of interest

Kang, HJ, Bae, KY, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Park, SW, Kim, YH, Yoon, JS, Kim, JM. Associations between Serotonergic Genes and Escitalopram Treatment Responses in Patients with Depressive Disorder and Acute Coronary Syndrome: The EsDEPACS Study. Psychiatry Investig. 2016;13(1):157–60. DOI: 10.4306/pi.2016.13.1.157. PMID: 26766959.26766959
Kang, HJ, Bae, KY, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Yoon, JS, Kim, JM. BDNF val66met polymorphism and depressive disorders in patients with acute coronary syndrome. J Affect Disord. 2016;194:1–8. DOI: 10.1016/j.jad.2016.01.033. PMID: 26795846.26795846
Kang, HJ, Stewart, R, Bae, KY, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Yoon, JS, Kim, JM. Effects of depression screening on psychiatric outcomes in patients with acute coronary syndrome: Findings from the K-DEPACS and EsDEPACS studies. Int J Cardiol. 2015;190:114–21. DOI: 10.1016/j.ijcard.2015.04.164. PMID: 25918060.25918060
Kang, HJ, Stewart, R, Bae, KY, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Yoon, JS, Kim, JM. Predictors of depressive disorder following acute coronary syndrome: Results from K-DEPACS and EsDEPACS. J Affect Disord. 2015;181:1–8. DOI: 10.1016/j.jad.2015.04.004. PMID: 25913538.25913538
Kim, JM, Bae, KY, Stewart, R, Jung, BO, Kang, HJ, Kim, SW, Shin, IS, Hong, YJ, Kim, JH, Shin, HY, Kang, G, Ahn, Y, Kim, JK, Jeong, MH, Yoon, JS. Escitalopram treatment for depressive disorder following acute coronary syndrome: a 24-week double-blind, placebo-controlled trial. J Clin Psychiatry. 2015;76(1):62–8. DOI: 10.4088/JCP.14m09281. PMID: 25375836.25375836
Kim, JM, Kang, HJ, Bae, KY, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Kang, H, Yoon, JS. Determinants and escitalopram treatment effects on suicidal ideation in patients with acute coronary syndrome: Findings from the K-DEPACS and EsDEPACS studies. Int J Cardiol. 2016;219:225–30. DOI: 10.1016/j.ijcard.2016.06.048. PMID: 27336191.27336191
Kim, JM, Stewart, R, Bae, KY, Kang, HJ, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Yoon, JS. Correlates and Escitalopram Treatment Effects on Sleep Disturbance in Patients with Acute Coronary Syndrome: K-DEPACS and EsDEPACS. Sleep. 2015;38(7):1105–11. DOI: 10.5665/sleep.4822. PMID: 25581916.25581916
Kim, JM, Stewart, R, Bae, KY, Kang, HJ, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Yoon, JS. Effects of depression co-morbidity and treatment on quality of life in patients with acute coronary syndrome: the Korean depression in ACS (K-DEPACS) and the escitalopram for depression in ACS (EsDEPACS) study. Psychol Med. 2015;45(8):1641–52. DOI: 10.1017/s003329171400275x. PMID: 25412614.25412614
Kim, JM, Stewart, R, Kang, HJ, Bae, KY, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Yoon, JS. BDNF methylation and depressive disorder in acute coronary syndrome: The K-DEPACS and EsDEPACS studies. Psychoneuroendocrinology. 2015;62:159–65. DOI: 10.1016/j.psyneuen.2015.08.013. PMID: 26313133.26313133
Kim, SW, Bae, KY, Kim, JM, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Berk, M, Yoon, JS. The use of statins for the treatment of depression in patients with acute coronary syndrome. Transl Psychiatry. 2015;5:e620. DOI: 10.1038/tp.2015.116. PMID: 26285130.26285130
Kim, SY, Stewart, R, Bae, KY, Kim, SW, Shin, IS, Hong, YJ, Ahn, Y, Jeong, MH, Yoon, JS, Kim, JM. Influences of the Big Five personality traits on the treatment response and longitudinal course of depression in patients with acute coronary syndrome: A randomised controlled trial. J Affect Disord. 2016;203:38–45. DOI: 10.1016/j.jad.2016.05.071. PMID: 27280961.27280961

## Treatment study population did not have either (1) a criterion-based diagnosis of depression or (2) clinically important depressive symptoms using a validated depression scale

Bambauer, KZ, Aupont, O, Stone, PH, Locke, SE, Mullan, MG, Colagiovanni, J, McLaughlin, TJ. The effect of a telephone counseling intervention on self-rated health of cardiac patients. Psychosom Med. 2005;67(4):539–45. DOI:10.1097/01.psy.0000171810.37958.61. PMID: 16046365.16046365
McLaughlin, TJ, Aupont, O, Bambauer, KZ, Stone, P, Mullan, MG, Colagiovanni, J, Polishuk, E, Johnstone, M, Locke, SE. Improving psychologic adjustment to chronic illness in cardiac patients. The role of depression and anxiety. J Gen Intern Med. 2005;20(12):1084–90. DOI: 10.1111/j.1525-1497.2005.00256.x. PMID: 16423095.16423095
O’Neil, A, Taylor, B, Hare, DL, Sanderson, K, Cyril, S, Venugopal, K, Chan, B, Atherton, JJ, Hawkes, A, Walters, DL, Oldenburg, B. Long-term efficacy of a tele-health intervention for acute coronary syndrome patients with depression: 12-month results of the MoodCare randomized controlled trial. Eur J Prev Cardiol. 2015;22(9):1111–20. DOI: 10.1177/2047487314547655. PMID: 25159700.25159700
O’Neil, A, Taylor, B, Sanderson, K, Cyril, S, Chan, B, Hawkes, AL, Hare, DL, Jelinek, M, Venugopal, K, Atherton, JJ, Amerena, J, Grigg, L, Walters, DL, Oldenburg, B. Efficacy and feasibility of a tele-health intervention for acute coronary syndrome patients with depression: results of the “MoodCare” randomized controlled trial. Ann Behav Med. 2014;48(2):163–74. DOI: 10.1007/s12160-014-9592-0. PMID: 24570217.24570217