# Appendix D List of Included Studies

Bambauer, Kara Zivin, Locke, Steven E, Aupont, Onesky, Mullan, Mariquita G, McLaughlin, Thomas J. Using the Hospital Anxiety and Depression Scale to screen for depression in cardiac patients. General Hospital Psychiatry. 2005;27(4):275–284. DOI: 10.1016/j.genhosppsych.2005.03.002. PMID: 2005-08290-009.15993261
Banankhah, SK, Friedmann, E, Thomas, S. Effective treatment of depression improves post-myocardial infarction survival. World J Cardiol. 2015;7(4):215–23. DOI: 10.4330/wjc.v7.i4.215. PMID: 25914790.25914790
Berkman, LF, Blumenthal, J, Burg, M, Carney, RM, Catellier, D, Cowan, MJ, Czajkowski, SM, DeBusk, R, Hosking, J, Jaffe, A, Kaufmann, PG, Mitchell, P, Norman, J, Powell, LH, Raczynski, JM, Schneiderman, N. Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. Jama. 2003;289(23):3106–16. DOI: 10.1001/jama.289.23.3106. PMID: 12813116.12813116
Bunevicius, A, Staniute, M, Brozaitiene, J, Bunevicius, R. Diagnostic accuracy of self-rating scales for screening of depression in coronary artery disease patients. J Psychosom Res. 2012;72(1):22–5. DOI: 10.1016/j.jpsychores.2011.10.006. PMID: 22200518.22200518
Carney, RM, Blumenthal, JA, Freedland, KE, Youngblood, M, Veith, RC, Burg, MM, Cornell, C, Saab, PG, Kaufmann, PG, Czajkowski, SM, Jaffe, AS. Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. 2004;66(4):466–74. DOI: 10.1097/01.psy.0000133362.75075.a6. PMID: 15272090.15272090
Cowan, MJ, Freedland, KE, Burg, MM, Saab, PG, Youngblood, ME, Cornell, CE, Powell, LH, Czajkowski, SM. Predictors of treatment response for depression and inadequate social support--the ENRICHD randomized clinical trial. Psychother Psychosom. 2008;77(1):27–37. DOI: 10.1159/000110057. PMID: 18087205.18087205
Davidson, KW, Bigger, JT, Burg, MM, Carney, RM, Chaplin, WF, Czajkowski, S, Dornelas, E, Duer-Hefele, J, Frasure-Smith, N, Freedland, KE, Haas, DC, Jaffe, AS, Ladapo, JA, Lesperance, F, Medina, V, Newman, JD, Osorio, GA, Parsons, F, Schwartz, JE, Shaffer, JA, Shapiro, PA, Sheps, DS, Vaccarino, V, Whang, W, Ye, S. Centralized, stepped, patient preference-based treatment for patients with post-acute coronary syndrome depression: CODIACS vanguard randomized controlled trial. JAMA Intern Med. 2013;173(11):997–1004. DOI: 10.1001/jamainternmed.2013.915. PMID: 23471421.23471421
Davidson, KW, Rieckmann, N, Clemow, L, Schwartz, JE, Shimbo, D, Medina, V, Albanese, G, Kronish, I, Hegel, M, Burg, MM. Enhanced depression care for patients with acute coronary syndrome and persistent depressive symptoms: coronary psychosocial evaluation studies randomized controlled trial. Arch Intern Med. 2010;170(7):600–8. DOI: 10.1001/archinternmed.2010.29. PMID: 20386003.20386003
Frasure-Smith, N, Lesperance, F. Depression and anxiety as predictors of 2-year cardiac events in patients with stable coronary artery disease. Arch Gen Psychiatry. 2008;65(1):62–71. DOI: 10.1001/archgenpsychiatry.2007.4. PMID: 18180430.18180430
Huffman, JC, Smith, FA, Blais, MA, Beiser, ME, Januzzi, JL, Fricchione, GL. Rapid screening for major depression in post-myocardial infarction patients: an investigation using Beck Depression Inventory II items. Heart. 2006;92(11):1656–60. DOI: 10.1136/hrt.2005.087213. PMID: 16644855.16644855
Huffman, Jeff C, Doughty, Christopher T, Januzzi, James L, Pirl, William F, Smith, Felicia A., Fricchione, Gregory L.. Screening for major depression in post-myocardial infarction patients: Operating characteristics of the Beck-Depression Inventory-II. International Journal of Psychiatry in Medicine. 2010;40(2):187–197. DOI: 10.2190/PM.40.2.e. PMID: 2010-18061-005.20848875
Kronish, IM, Rieckmann, N, Burg, MM, Edmondson, D, Schwartz, JE, Davidson, KW. The effect of enhanced depression care on adherence to risk-reducing behaviors after acute coronary syndromes: findings from the COPES trial. Am Heart J. 2012;164(4):524–9. DOI: 10.1016/j.ahj.2012.07.024. PMID: 23067910.23067910
Low, Gail D, Hubley, Anita M. Screening for depression after cardiac events using the Beck Depression Inventory-II and the Geriatric Depression Scale. Social Indicators Research. 2007;82(3):527–548. DOI: 10.1007/s11205-006-9049-3. PMID: 2008-08604-008.
McGuire, AW, Eastwood, JA, Macabasco-O’Connell, A, Hays, RD, Doering, LV. Depression screening: utility of the patient health questionnaire in patients with acute coronary syndrome. Am J Crit Care. 2013;22(1):12–9. DOI: 10.4037/ajcc2013899. PMID: 23283084.23283084
Mendes de Leon, CF, Czajkowski, SM, Freedland, KE, Bang, H, Powell, LH, Wu, C, Burg, MM, DiLillo, V, Ironson, G, Krumholz, HM, Mitchell, P, Blumenthal, JA. The effect of a psychosocial intervention and quality of life after acute myocardial infarction: the Enhancing Recovery in Coronary Heart Disease (ENRICHD) clinical trial. J Cardiopulm Rehabil. 2006;26(1):9–13; quiz 14–5. PMID: 16617220.16617220
Roest, AM, Carney, RM, Freedland, KE, Martens, E J, Denollet, J, de Jonge, P. Changes in cognitive versus somatic symptoms of depression and event-free survival following acute myocardial infarction in the Enhancing Recovery In Coronary Heart Disease (ENRICHD) study. J Affect Disord. 2013;149(1–3):335–41. DOI: 10.1016/j.jad.2013.02.008. PMID: 23489396.23489396
Saab, PG, Bang, H, Williams, RB, Powell, LH, Schneiderman, N, Thoresen, C, Burg, M, Keefe, F. The impact of cognitive behavioral group training on event-free survival in patients with myocardial infarction: the ENRICHD experience. J Psychosom Res. 2009;67(1):45–56. DOI: 10.1016/j.jpsychores.2009.01.015. PMID: 19539818.19539818
Schneiderman, N, Saab, PG, Catellier, DJ, Powell, LH, DeBusk, RF, Williams, RB, Carney, RM, Raczynski, JM, Cowan, MJ, Berkman, LF, Kaufmann, PG. Psychosocial treatment within sex by ethnicity subgroups in the Enhancing Recovery in Coronary Heart Disease clinical trial. Psychosom Med. 2004;66(4):475–83. DOI: 10.1097/01.psy.0000133217.96180.e8. PMID: 15272091.15272091
van Melle, JP, de Jonge, P, Honig, A, Schene, AH, Kuyper, AM, Crijns, HJ, Schins, A, Tulner, D, van den Berg, MP, Ormel, J. Effects of antidepressant treatment following myocardial infarction. Br J Psychiatry. 2007;190:460–6. DOI: 10.1192/bjp.bp.106.028647. PMID: 17541103.17541103
Ye, S, Shaffer, JA, Rieckmann, N, Schwartz, JE, Kronish, IM, Ladapo, JA, Whang, W, Burg, MM, Davidson, KW. Long-term outcomes of enhanced depression treatment in patients with acute coronary syndromes. Am J Med. 2014;127(10):1012–6. DOI: 10.1016/j.amjmed.2014.05.004. PMID: 24835038.24835038
Zuidersma, M, Conradi, HJ, van Melle, JP, Ormel, J, de Jonge, P. Depression treatment after myocardial infarction and long-term risk of subsequent cardiovascular events and mortality: a randomized controlled trial. J Psychosom Res. 2013;74(1):25–30. DOI: 10.1016/j.jpsychores.2012.08.015. PMID: 23272985.23272985