# Appendix C Data Abstraction Elements

## Study Characteristics

- Study Identifiers
  ○ Study Name or Acronym
  ○ NCT number or other trial registry identifier
  ○ Last name of first author
- Additional Articles Used in This Abstraction
- Purpose of the Study
- Key Question Applicability (Select all that apply):
  ○ KQ1, KQ2
- Study Sites:
  ○ Single center, Multicenter, Unclear/Not reported
- Geographic Location (Select all that apply):
  ○ US, Canada, UK/Europe, Latin America, Middle East (includes Israel), Asia, Africa, Australia/New Zealand, Unclear/Not reported
- Study Design:
  ○ Observational
  ○ RCT
  ○ Cluster RCT
- Funding Source (Select all that apply):
  ○ Government, Industry, Non-government/non-industry, Unclear/Not reported
- Setting (Select all that apply):
  ○ Outpatient, Inpatient, Other (specify), Unclear/Not reported
- Study Enrollment/Study Completion
  ○ Is the entire population of the study relevant to this review, or only a portion?:
    ■ Entire study population, Only a portion of the study population
  ○ For the relevant population:
    ■ N enrolled/included
    ■ N completed (those who completed the final outcome assessment of the primary study publication)
  ○ Data reported for any subgroups of interest? (Select all that apply):
    ■ Age (older adults [≥ 65 years] versus adults younger than 65 years of age), Race/ethnicity, Sex, In- vs outpatient, None
  ○ Is the study population entirely composed of a population that falls into a subgroup of interest?: (Select all that apply)
    ■ No, Yes
    ■ If yes, specify the subgroup category.
- Cardiac-related inclusion criteria used in the study
- Comments

## Baseline Characteristics

- Record the following elements for Total Population, Arm 1, Arm 2, Arm 3, Arm 4, and Arm 5 (as applicable)
  ○ Number of Patients (N; and for individual arms, %)
  ○ Age in Years
    ■ Mean
    ■ Median
    ■ Standard Deviation
    ■ Min
    ■ Max
    ■ 25% IQR
    ■ 75% IQR
    ■ Categorical (describe)
    ■ Other, specify
  ○ Proportion of Women and Men (N and %)
  ○ Race/Ethnicity (N and %)
    ■ Hispanic or Latino
    ■ Black/African American
    ■ American Indian or Alaska Native
    ■ Asian
    ■ Native Hawaiian or Pacific Islander
    ■ White
    ■ Multiracial
    ■ Other (specify)
    ■ Unknown
  ○ Socioeconomic Factors (Indicate elements reported and describe data)
    ■ Insurance Status
    ■ Income Level
    ■ Social Class
    ■ Level of Education
    ■ Other
    ■ Unclear or NR
  ○ Depression Severity (Indicate elements reported and describe data)
    ■ PHQ-9 Continuous Measure
    ■ Other Continuous Measures
    ■ Categorical Measures
    ■ Unclear or NR
  ○ Cardiac Severity (Indicate elements reported and describe data)
    ■ Type of ACS Event
    ■ Functional Class
    ■ LV function
    ■ Unclear or NR
  ○ Renal Function
    ■ If reported - list measure and describe data
    ■ Unclear or NR
- Comments

## KQ 1 Intervention Characteristics and Outcomes

- For Each Tool of Interest Assessed, Specify:
  ○ Tool name
  ○ Number of questions
  ○ Mode of administration
  ○ N patients assessed
- Criterion Standard (Specify the following):
  ○ Tool/type
  ○ N patients assessed
  ○ Mode of administration
- Prevalence of Post-ACS Depression in the Population
- Timing of Screening
- Threshold(s) Considered
- Record the following for selected thresholds and populations assessed:
  ○ Major Depressive Disorder
    ■ Chosen threshold
    ■ Threshold rationale
    ■ Sensitivity (%)
    ■ Sensitivity (%)
    ■ PPV (%)
    ■ NPV (%)
    ■ AUC
    ■ p value
  ○ Major Depressive Disorder and Dysthymic Disorder
    ■ Chosen threshold
    ■ Threshold rationale
    ■ Sensitivity (%)
    ■ Sensitivity (%)
    ■ PPV (%)
    ■ NPV (%)
    ■ AUC
    ■ p value
  ○ Major Depressive Disorder (MDD), MDD and Dysthymic Disorder, Minor Depressive Disorder, Partial Remission of MDD, or Dysthymic Disorder
    ■ Chosen threshold
    ■ Threshold rationale
    ■ Sensitivity (%)
    ■ Sensitivity (%)
    ■ PPV (%)
    ■ NPV (%)
    ■ AUC
    ■ p value

## KQ 2 Intervention Characteristics

- High Level Intervention/Comparison (Select all that apply):
  ○ KQ 2: Medical therapy vs Medical therapy
  ○ KQ 2: Medical therapy vs Psychotherapy
  ○ KQ 2: Medical therapy vs Other treatment
  ○ KQ 2: Medical therapy vs Enhanced care delivery
  ○ KQ 2: Medical therapy vs Usual care
  ○ KQ 2: Psychotherapy vs Psychotherapy
  ○ KQ 2: Psychotherapy vs Other treatment
  ○ KQ 2: Psychotherapy vs Enhanced care delivery
  ○ KQ 2: Psychotherapy vs Usual care
  ○ KQ 2: Other treatment vs Other treatment
  ○ KQ 2: Other treatment vs Enhanced care delivery
  ○ KQ 2: Other treatment vs Usual care
  ○ KQ 2: Enhanced care delivery vs Enhanced care delivery
  ○ KQ 2: Enhanced care delivery vs Usual care
  ○ KQ 2: Combination of categories vs a single category or another combination (describe)
- If applicable, describe the Usual care intervention
- Intervention Descriptors (For each arm)
  ○ Describe the intervention received by the patient group.
  ○ Categorize the Depression-Focused Intervention (Select all that apply):
    ■ Medical Therapy
    ■ Psychotherapy
    ■ Enhanced Care Delivery
    ■ Other treatments (e.g., aerobic exercise, fish oils) - specify
    ■ Usual Care
  ○ Provide a Descriptive Label for the Depression-Focused Intervention
- Comments

## KQ 2 Outcomes

- Select the Category of Outcome Reported:
  ○ Clinical outcomes, Quality of Life, Cost-effectiveness, Utilization of healthcare services, Discontinuation of depression intervention due to adverse effects, Adverse effects of treatment
- Select the Specific Outcome Reported:
  ○ Clinical outcomes
    ■ Total mortality
    ■ Depression related outcomes: Response or remission of depressive symptoms using validated continuous or categorical measures
    ■ Cardiac mortality
    ■ Repeat ACS event (repeat MI or unstable angina)
    ■ Resuscitated arrest
    ■ Stroke
    ■ Arrhythmias
    ■ Revascularization
    ■ MACE composite
  ○ Quality of Life
  ○ Cost-effectiveness
  ○ Utilization of healthcare services
    ■ Cardiac medication adherence
    ■ Readmission rates due to cardiac and non-cardiac reasons
    ■ Emergency room visits: all visits
    ■ Emergency room visits: cardiac-related
    ■ Emergency room visits: psychiatric-related
    ■ Hospitalization
  ○ Discontinuation of depression intervention due to adverse effects
  ○ Adverse effects of treatment
    ■ Weight gain
    ■ GI bleeding
    ■ Arrhythmias
    ■ Suicidal ideation, behaviors, or attempts
- Describe the outcome measure represented on this form
- Categorize timing of the outcome:
  ○ During hospitalization/at discharge
  ○ Within 30 days of hospitalization for an acute ACS event
  ○ Within 3 months of hospitalization for an acute ACS event
  ○ Beyond 3 months of hospitalization for an acute ACS event
  ○ Unclear
- Record the specific timepoint for this outcome
- Select outcome type (Continuous or Categorical)
  ○ If Continuous:
    ■ Label intervention
    ■ Label comparator
    ■ Record available baseline data:
      - Intervention
        ○ N
        ○ Baseline Average (mean, median, NR)
        ○ Baseline Variability (SD, IQR, Range, SE, NR)
      - Comparator
        ○ N
        ○ Baseline Average
        ○ Baseline Variability
        ○ NR
      - NR
    ■ Record available follow-up data:
      - Intervention
        ○ N analyzed
        ○ Average (mean at follow-up, median at follow-up, within group difference, NR)
        ○ Variability (SD, IQR, Range, SE, 95% CI, NR)
      - Comparator
        ○ N analyzed
        ○ Average
        ○ Variability
        ○ NR
      - Effect Estimate
        ○ N analyzed
        ○ Effect size (mean difference, regression coefficient, Cohen’s d, Hedges’ g, NR)
        ○ Variability (95% CI, SE, value, Other, NR)
  ○ If Categorical
    ■ Label intervention
    ■ Label comparator
    ■ Intervention
      - N with event
      - N denominator
      - NR
    ■ Comparator
      - N with event
      - N denominator
      - NR
    ■ Effect Estimate
      - Between group effect (OR, RR, HR, NR)
      - Variance (95% CI, SE, p value, NR)
- Comments

## Quality

- Applicable KQ (select one):
  ○ KQ 1 (QUADAS-2 Tool)
  ○ KQ 2 (Cochrane Tool)
- If KQ 1, rate each individual element as Yes/No/Unclear, then rate each domain as Low/High/Unclear risk of bias.
  ○ Patient Selection
    ■ Individual Elements:
      - Was a consecutive or random sample of patients enrolled?
      - Was a case-control design avoided?
      - Did the study avoid inappropriate exclusions?
    ■ Domain summary: Could the selection of patients have introduced bias? (Indicate risk: Low/High/Unclear)
  ○ Index Tests
    ■ Individual Elements:
      - Were the index test results interpreted without knowledge of the reference standard?
      - If a threshold was used, was it pre-specified?
    ■ Domain summary: Could the conduct or interpretation of the index test have introduced bias? (Indicate risk: Low/High/Unclear)
  ○ Reference Standards
    ■ Individual Elements:
      - Is the reference standard likely to correctly classify the target condition?
      - Were the reference standard results interpreted without knowledge of the results of the index test?
    ■ Domain summary: Could the reference standard, its conduct, or its interpretation have introduced bias? (Indicate risk: Low/High/Unclear)
  ○ Flow and Timing
    ■ Individual Elements:
      - Was there an appropriate interval between index test(s) and reference standard?
      - Did all patients receive a reference standard?
      - Did all patients receive the same reference standard?
      - Were all patients included in the analysis?
    ■ Domain summary: Could the patient flow have introduced bias? (Indicate risk: Low/High/Unclear)
- If KQ 2, rate each domain item listed as Low/High/Unclear risk and describe:
  ○ Random sequence generation
  ○ Allocation concealment
  ○ Blinding of participants and personnel
  ○ Blinding of outcome assessment
  ○ Incomplete outcome data
  ○ Selective reporting
  ○ Other Bias
- If KQ2, rate the overall study risk of bias (Good/Fair/Poor)
  ○ Good (low risk of bias). These studies have the least bias, and the results are considered valid. These studies adhere to the commonly held concepts of high quality, including the following: a clear description of the population, setting, approaches, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytical methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
  ○ Fair. These studies are susceptible to some bias, but not enough to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
  ○ Poor (high risk of bias). These studies have significant flaws that may have invalidated the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.
  ○ If the study is rated as “Fair” or “Poor,” provide rationale.
- Outcome-specific quality rating
  ○ Should any of the outcomes abstracted for this study should be assigned a quality rating different from the overall study rating? (No/Yes)
    ■ If yes, provide the outcome(s), rating(s), and rationale(s).
- Comments

## Applicability

Use the PICOS format to identify specific issues, if any, which may limit the applicability of the study.

- Population (P)
  ○ Narrow eligibility criteria and exclusion of those with comorbidities
  ○ More complex patients than typical of the community
  ○ Run-in period with high exclusion rate for non-adherence or side effects
- Intervention (I)
  ○ Diagnostic tools used differently than as recommended or commonly used in practice
  ○ Dosing not reflective of current practice
  ○ Co-interventions that are likely to modify the effectiveness of therapy
  ○ Highly selected intervention team or level of training/proficiency not widely available
  ○ Follow-up not reflective of current practice
- Comparator (C)
  ○ Diagnostic tools used differently than as recommended or commonly used in practice
  ○ Comparator unclear
  ○ Inadequate comparison therapy or use of a substandard alternative therapy
- Outcomes (O)
  ○ Composite outcomes that mix outcomes of different significance
  ○ Short-term follow-up
  ○ Surrogate outcomes
- Setting (S)
  ○ Level of care different from that in the community
- Any other concerns regarding the applicability of this study? (Yes/No)
  ○ If yes, describe.
- Comments