# Appendix B Exact Search Strings

## PubMed^®^ Search Strategy (August 15, 2017)

### KQ 1

Search Number | Search String
#1 | “Myocardial Infarction”[Mesh] OR “myocardial infarction”[tiab] OR “myocardial infarct”[tiab] OR “myocardial infarctions”[tiab] OR “heart infarction”[tiab] OR “heart infarct”[tiab] OR “heart infarctions”[tiab] OR “heart attack”[tiab] OR “heart attacks”[tiab]
#2 | “Acute Coronary Syndrome”[Mesh] OR “acute coronary syndrome”[tiab]
#3 | “Depression”[Mesh] OR “Mental Disorders”[Mesh] OR depression[tiab] OR depressive[tiab] OR “mood disorder”[tiab] OR “mood disorders”[tiab] OR “psychiatric disorder”[tiab] OR “psychiatric disorders”[tiab]
#4 | “Depression/diagnosis”[Mesh] OR mass screening[mesh] OR questionnaires[mesh] OR Interviews as Topic[Mesh] OR Psychometrics[Mesh] OR Psychiatric Status Rating Scales[Mesh] OR questionnaire[tiab] OR questionnaires[tiab] OR screening[tiab] OR screen[tiab] OR scale[tiab] OR instrument[tiab] OR instruments[tiab] OR inventory[tiab] OR BDI[tiab] OR “beck depression inventory”[tiab] OR CES-D20[tiab] OR CES-D10[tiab] OR “Center for Epidemiologic Studies Depression Scale”[tiab] OR HADS[tiab] OR “HADS-D”[tiab] OR “Hospital Anxiety and Depression Scale”[tiab] OR PHQ-9[tiab] OR “Patient Health Questionnaire-9”[tiab] OR PHQ-8[tiab] OR “Patient Health Questionnaire-8”[tiab] OR “Zung SDS”[tiab] OR “Zung Self-Rating Depression Scale”[tiab] OR “Zung Self Assessment Depression Scale”[tiab] OR “symptom checklist 20”[tiab] OR “Hopkins symptom checklist”[tiab] OR “Kessler psychological distress scale”[tiab] OR “distress questionnaire 5”[tiab] OR “geriatric depression scale”[tiab] OR “gds-15”[tiab] OR “primary care rapid evaluation of mental disorders”[tiab] OR “prime-md”[tiab] OR “duke anxiety and depression scale”[tiab] OR “inventory to diagnose depression”[tiab] OR “IDS”[tiab] OR “world health organization 5”[tiab] OR “who-5”[tiab] OR “Quick Inventory of Depressive Symptomatology”[tiab] OR promis[tiab] OR “patient reported outcomes measurement information system”[tiab]
#5 | (systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “Cross-Sectional Studies”[Mesh] OR “cross sectional”[tiab]”evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tiab] OR evaluation studies[tiab] OR “intervention study”[tiab] OR “intervention studies”[tiab] OR “case-control studies”[MeSH Terms] OR “case-control”[tiab] OR “cohort studies”[MeSH Terms] OR cohort[tiab] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tiab] OR longitudinally[tiab] OR “prospective”[tiab] OR prospectively[tiab] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tiab] OR “follow up”[tiab] OR “comparative study”[Publication Type] OR “comparative study”[tiab]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh]) AND English[la] AND (“2003/01/01”[Date - Publication] : “3000”[Date - Publication])
# 6 | (#1 OR #2) AND #3 AND #4 AND #5

### KQ 2

Search Number | Search String
#1 | “Myocardial Infarction”[Mesh] OR “myocardial infarction”[tiab] OR “myocardial infarct”[tiab] OR “myocardial infarctions”[tiab] OR “heart infarction”[tiab] OR “heart infarct”[tiab] OR “heart infarctions”[tiab] OR “heart attack”[tiab] OR “heart attacks”[tiab]
#2 | “Acute Coronary Syndrome”[Mesh] OR “acute coronary syndrome”[tiab]
#3 | “Depression”[Mesh] OR “Mental Disorders”[Mesh] OR depression[tiab] OR depressive[tiab] OR “mood disorder”[tiab] OR “mood disorders”[tiab] OR “psychiatric disorder”[tiab] OR “psychiatric disorders”[tiab]
#4 | “Depression/therapy”[Mesh] OR “Antidepressive Agents”[Mesh] OR “Antidepressive Agents” [Pharmacological Action] OR “Antidepressive Agents, Tricyclic” [Pharmacological Action] OR “Antidepressive Agents, Second-Generation” [Pharmacological Action] OR “Aripiprazole”[Mesh] OR “olanzapine”[Supplementary Concept] OR “Quetiapine Fumarate”[Mesh] OR “Fish Oils”[Mesh] OR “Psychotherapy”[Mesh] OR “Exercise”[Mesh] OR “Physical Therapy Modalities”[Mesh] OR “Cardiovascular Diseases/rehabilitation”[Majr] OR “Hypericum”[Mesh] OR “Health Education”[Mesh] OR “Stress, Psychological”[Mesh] OR “Adaptation, Psychological”[Mesh] OR “Electroconvulsive Therapy”[Mesh] OR “continuity of patient care”[mesh] OR “Delivery of Health Care, Integrated”[Mesh] OR “Patient Care Team”[Mesh] OR “Patient Care Planning”[Mesh] OR “Disease Management”[Mesh] OR “Comprehensive Health Care”[Mesh:NoExp] OR “Patient Care Management”[Mesh:NoExp] OR “Transcranial Magnetic Stimulation”[Mesh] OR “S-Adenosylmethionine”[Mesh] OR amitriptyline[tiab] OR bupropion[tiab] OR citalopram[tiab] OR Desipramine[tiab] OR desvenlafaxine[tiab] OR Doxepin[tiab] OR duloxetine[tiab] OR fluoxetine[tiab] OR escitalopram[tiab] OR Imipramine[tiab] OR levomilnacipran[tiab] OR mirtazapine[tiab] OR nefazodone[tiab] OR paroxetine[tiab] OR Protriptyline[tiab] OR sertraline[tiab] OR trazodone[tiab] OR Trimipramine[tiab] OR venlafaxine[tiab] OR vilazodone[tiab] OR vortioxetine[tiab] OR aripiprazole[tiab] OR nortriptyline[tiab] OR olanzapine[tiab] OR quetiapine[tiab] OR Amoxapine[tiab] OR antidepressants[tiab] OR antidepressant[tiab] OR “fish oil”[tiab] OR “fish oils”[tiab] OR “fatty acid”[tiab] OR “fatty acids”[tiab] OR “omega 3”[tiab] OR “psychotherapy”[tiab] OR “behavior therapy”[tiab] OR “behavioral therapy”[tiab] OR “behaviour therapy”[tiab] OR “behavioural therapy”[tiab] OR “cognitive therapy”[tiab] OR “problem solving therapy”[tiab] OR “psychodynamic therapy”[tiab] OR mindfulness[tiab] OR “acceptance and commitment therapy”[tiab] OR “behavioral activation”[tiab] OR “behavioural activation”[tiab] OR “behavioral action”[tiab] OR “behavioural action”[tiab] OR exercise[tiab] OR psychosocial[tiab] OR “cardiac rehabilitation”[tiab] OR “physical therapy”[tiab] OR hypericum[tiab] OR “st john’s wort”[tiab] OR “saint john’s wort”[tiab] OR education[tiab] OR psychoeducation[tiab] OR stress[tiab] OR “collaborative care”[tiab] OR “care management”[tiab] OR “case management”[tiab] OR “disease management”[tiab] OR “enhanced care”[tiab] OR “managed care”[tiab] OR multidisciplinary[tiab] OR interprofessional[tiab] OR “team care”[tiab] OR “team consultation”[tiab] OR “team treatment”[tiab] OR “shared care”[tiab] OR “Transcranial Magnetic Stimulation”[tiab] OR “S-Adenosylmethionine”[tiab]
#5 | (systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) AND English[la] AND (“2003/01/01”[Date - Publication] : “3000”[Date - Publication])
#6 | (#1 OR #2) AND #3 AND #4 AND #5

## Embase^®^ Search Strategy (August 15, 2017)

Platform: Embase.com

### KQ 1

Search Number | Search String
#1 | ‘heart infarction’/exp OR “myocardial infarction”:ab,ti OR “myocardial infarct”:ab,ti OR “myocardial infarctions”:ab,ti OR “heart infarction”:ab,ti OR “heart infarct”:ab,ti OR “heart infarctions”:ab,ti OR “heart attack”:ab,ti OR “heart attacks”:ab,ti
#2 | ‘acute coronary syndrome’/exp OR ‘acute coronary syndrome’:ab,ti
#3 | ‘mental disease’/exp OR depression:ab,ti OR depressive:ab,ti OR “mood disorder”:ab,ti OR “mood disorders”:ab,ti OR “psychiatric disorder”:ab,ti OR “psychiatric disorders”:ab,ti
#4 | ‘depression’/exp/dm_di OR ‘screening’/exp OR ‘questionnaire’/exp OR ‘interview’/exp OR ‘Beck Depression Inventory’/exp OR ‘Center for Epidemiological Studies Depression Scale’/exp OR ‘Hospital Anxiety and Depression Scale’/exp OR ‘psychometry’/exp OR ‘psychological rating scale’/exp OR questionnaire:ab,ti OR questionnaires:ab,ti OR screening:ab,ti OR screen:ab,ti OR scale:ab,ti OR instrument:ab,ti OR instruments:ab,ti OR inventory:ab,ti OR BDI:ab,ti OR “beck depression inventory”:ab,ti OR “CES D20”:ab,ti OR “CES D10”:ab,ti OR “Center for Epidemiologic Studies Depression Scale”:ab,ti OR HADS:ab,ti OR “HADS D”:ab,ti OR “Hospital Anxiety and Depression Scale”:ab,ti OR “PHQ 9”:ab,ti OR “Patient Health Questionnaire 9”:ab,ti OR “PHQ 8”:ab,ti OR “Patient Health Questionnaire 8”:ab,ti OR “Zung SDS”:ab,ti OR “Zung Self Rating Depression Scale”:ab,ti OR “Zung Self Assessment Depression Scale”:ab,ti OR “symptom checklist 20”:ab,ti OR “Hopkins symptom checklist”:ab,ti OR “Kessler psychological distress scale”:ab,ti OR “distress questionnaire 5”:ab,ti OR “geriatric depression scale”:ab,ti OR “gds 15”:ab,ti OR “primary care rapid evaluation of mental disorders”:ab,ti OR “prime md”:ab,ti OR “duke anxiety and depression scale”:ab,ti OR “inventory to diagnose depression”:ab,ti OR “world health organization 5”:ab,ti OR “who 5”:ab,ti OR “Quick Inventory of Depressive Symptomatology”:ab,ti OR promis:ab,ti OR “patient reported outcomes measurement information system”:ab,ti
#5 | (‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR ‘cross-sectional study’/exp OR ‘cross sectional’:ab,ti OR ‘evaluation study’:ab,ti OR ‘evaluation studies’:ab,ti OR ‘intervention study’:ab,ti OR ‘intervention studies’:ab,ti OR ‘case control’:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR ‘follow up’:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR ‘comparative study’:ab,ti OR ‘comparative studies’:ab,ti) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp OR [conference abstract]/lim) AND [2003–2017]/py AND [english]/lim AND [humans]/lim AND [embase]/lim NOT [medline]/lim
#6 | (#1 OR #2) AND #3 AND #4 AND #5

### KQ 2

Search Number | Search String
#1 | ‘heart infarction’/exp OR “myocardial infarction”:ab,ti OR “myocardial infarct”:ab,ti OR “myocardial infarctions”:ab,ti OR “heart infarction”:ab,ti OR “heart infarct”:ab,ti OR “heart infarctions”:ab,ti OR “heart attack”:ab,ti OR “heart attacks”:ab,ti
#2 | ‘acute coronary syndrome’/exp OR ‘acute coronary syndrome’:ab,ti
#3 | ‘mental disease’/exp OR depression:ab,ti OR depressive:ab,ti OR “mood disorder”:ab,ti OR “mood disorders”:ab,ti OR “psychiatric disorder”:ab,ti OR “psychiatric disorders”:ab,ti
#4 | ‘depression’/exp/dm_dt,dm_th,dm_rh,dm_dm,dm_pc OR ‘antidepressant agent’/exp OR ‘psychotherapy’/exp OR ‘exercise’/exp OR ‘physical medicine’/exp OR ‘heart rehabilitation’/exp OR ‘Hypericum’/exp OR ‘fish oil’/exp OR ‘omega 3 fatty acid’/exp OR ‘health education’/exp OR ‘mental stress’/exp OR ‘adaptive behavior’/exp OR ‘electroconvulsive therapy’/exp OR ‘transcranial magnetic stimulation’/exp OR ‘s adenosylmethionine’/exp OR bupropion:ab,ti OR citalopram:ab,ti OR desvenlafaxine:ab,ti OR duloxetine:ab,ti OR fluoxetine:ab,ti OR escitalopram:ab,ti OR levomilnacipran:ab,ti OR mirtazapine:ab,ti OR nefazodone:ab,ti OR paroxetine:ab,ti OR sertraline:ab,ti OR trazodone:ab,ti OR venlafaxine:ab,ti OR vilazodone:ab,ti OR vortioxetine:ab,ti OR amitriptyline:ab,ti OR Desipramine:ab,ti OR Doxepin:ab,ti OR Imipramine:ab,ti OR Protriptyline:ab,ti OR Trimipramine:ab,ti OR nortriptyline:ab,ti OR Amoxapine:ab,ti OR antidepressants:ab,ti OR antidepressant:ab,ti OR “fish oil”:ab,ti OR “fish oils”:ab,ti OR “fatty acid”:ab,ti OR “fatty acids”:ab,ti OR “omega 3”:ab,ti OR “psychotherapy”:ab,ti OR “behavior therapy”:ab,ti OR “behavioral therapy”:ab,ti OR “cognitive therapy”:ab,ti OR “problem solving therapy”:ab,ti OR “psychodynamic therapy”:ab,ti OR mindfulness:ab,ti OR “acceptance and commitment therapy”:ab,ti OR “reminiscence therapy”:ab,ti OR “behavioral action”:ab,ti OR “compassion-based therapy”:ab,ti OR exercise:ab,ti OR psychosocial:ab,ti OR “cardiac rehabilitation”:ab,ti OR “physical therapy”:ab,ti OR hypericum:ab,ti OR “st john* wort”:ab,ti OR “saint john* wort”:ab,ti OR education:ab,ti OR psychoeducation:ab,ti OR stress:ab,ti OR “collaborative care”:ab,ti OR “Transcranial Magnetic Stimulation”:ab,ti OR “S Adenosylmethionine”:ab,ti
#5 | (‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR ‘cross over’:ab,ti OR ‘cross overs’:ab,ti OR placebo*:ab,ti OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘double blind procedure’/exp OR ‘crossover procedure’/exp OR ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp) NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp OR [conference abstract]/lim) AND [2003–2017]/py AND [english]/lim AND [humans]/lim AND [embase]/lim NOT [medline]/lim
#6 | (#1 OR #2) AND #3 AND #4 AND #5

## Cochrane Search Strategy (August 15, 2017)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

Search Number | Search String
#1 | [mh “Myocardial Infarction”]
#2 | “myocardial infarction”:ab,ti OR “myocardial infarct”:ab,ti OR “myocardial infarctions”:ab,ti OR “heart infarction”:ab,ti OR “heart infarct”:ab,ti OR “heart infarctions”:ab,ti OR “heart attack”:ab,ti OR “heart attacks”:ab,ti
#3 | #1 OR #2
#4 | [mh “Acute Coronary Syndrome”]
#5 | “acute coronary syndrome”:ab,ti
#6 | #4 OR #5
#7 | [mh Depression] OR [mh “Mental Disorders”]
#8 | depression:ab,ti OR depressive:ab,ti OR “mood disorder”:ab,ti OR “mood disorders”:ab,ti OR “psychiatric disorder”:ab,ti OR “psychiatric disorders”:ab,ti
#9 | #7 OR #8
#10 | (#3 OR #6) AND #9

## PsycINFO Search Strategy (August 15, 2017)

### KQ 1

Search Number | Search String
#1 | DE “Myocardial Infarctions” OR TI ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” ) OR AB ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” )
#2 | TI (“acute coronary syndrome”) OR AB (“acute coronary syndrome”)
#3 | (DE “Depression (Emotion)”) OR (DE “Major Depression” OR DE “Anaclitic Depression” OR DE “Dysthymic Disorder” OR DE “Endogenous Depression” OR DE “Late Life Depression” OR DE “Reactive Depression” OR DE “Recurrent Depression” OR DE “Treatment Resistant Depression”) OR TI ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” ) OR AB ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” )
#4 | DE “Screening” OR DE “Screening Tests” OR DE “Psychological Screening Inventory” OR DE “Rating Scales” OR DE “Inventories” OR DE “Psychological Assessment” OR DE “Psychodiagnosis” OR DE “Psychodiagnostic Interview” OR DE “Questionnaires” OR DE “General Health Questionnaire” OR ((DE “Beck Depression Inventory”) OR (DE “Zungs Self Rating Depression Scale”)) OR TI (questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR inventory OR BDI OR “beck depression inventory” OR CES-D20 OR CES-D10 OR “Center for Epidemiologic Studies Depression Scale” OR HADS OR HADS-D OR “Hospital Anxiety and Depression Scale” OR PHQ-9 OR PHQ-8 OR “Patient Health Questionnaire” OR “Zung SDS” OR “Zung Self-Rating Depression Scale” OR “Zung Self Assessment Depression Scale” OR “symptom checklist 20” OR “Hopkins symptom checklist” OR “Kessler psychological distress scale” OR “distress questionnaire 5” OR “geriatric depression scale” OR “gds-15” OR “primary care rapid evaluation of mental disorders” OR “prime-md” OR “duke anxiety and depression scale” OR “inventory to diagnose depression” OR “world health organization 5” OR “who-5” OR “Quick Inventory of Depressive Symptomatology” OR promis OR “patient reported outcomes measurement information system”) OR AB (questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR inventory OR BDI OR “beck depression inventory” OR CES-D20 OR CES-D10 OR “Center for Epidemiologic Studies Depression Scale” OR HADS OR HADS-D OR “Hospital Anxiety and Depression Scale” OR PHQ-9 OR PHQ-8 OR “Patient Health Questionnaire” OR “Zung SDS” OR “Zung Self-Rating Depression Scale” OR “Zung Self Assessment Depression Scale” OR “symptom checklist 20” OR “Hopkins symptom checklist” OR “Kessler psychological distress scale” OR “distress questionnaire 5” OR “geriatric depression scale” OR “gds-15” OR OR “primary care rapid evaluation of mental disorders” OR “prime-md” OR “duke anxiety and depression scale” OR “inventory to diagnose depression” OR “world health organization 5” OR “who-5” OR “Quick Inventory of Depressive Symptomatology” OR promis OR “patient reported outcomes measurement information system”)
#5 | ZC “meta analysis” OR ZC “systematic review” OR DE “Meta Analysis” OR TI (“meta-analysis” OR “meta-analyses” OR “systematic review” OR “systematic reviews”) OR AB (“meta-analysis” OR “meta-analyses” OR “systematic review” OR “systematic reviews”) OR ZC “longitudinal study” OR ZC “empirical study” OR ZC “followup study” OR ZC “longitudinal study” OR ZC “prospective study” OR ZC “retrospective study” OR DE “Cohort Analysis” OR DE “Followup Studies” OR DE “Longitudinal Studies” OR DE “Prospective Studies” OR TI (“evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study”) OR AB (“evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study”) AND (ZZ “journal article”)
#6 | (S1 OR S2) AND S3 AND S4 AND S5 Limits: English, 2003 – present, Human

### KQ 2

Search Number | Search String
#1 | DE “Myocardial Infarctions” OR TI ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” ) OR AB ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” )
#2 | TI (“acute coronary syndrome”) OR AB (“acute coronary syndrome”)
#3 | (DE “Depression (Emotion)”) OR (DE “Major Depression” OR DE “Anaclitic Depression” OR DE “Dysthymic Disorder” OR DE “Endogenous Depression” OR DE “Late Life Depression” OR DE “Reactive Depression” OR DE “Recurrent Depression” OR DE “Treatment Resistant Depression”) OR TI ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” ) OR AB ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” )
#4 | DE “Antidepressant Drugs” OR DE “Bupropion” OR DE “Citalopram” OR DE “Fluoxetine” OR DE “Fluvoxamine” OR DE “Iproniazid” OR DE “Isocarboxazid” OR DE “Lithium Carbonate” OR DE “Methylphenidate” OR DE “Mianserin” OR DE “Moclobemide” OR DE “Molindone” OR DE “Nefazodone” OR DE “Nialamide” OR DE “Nomifensine” OR DE “Paroxetine” OR DE “Phenelzine” OR DE “Pheniprazine” OR DE “Pipradrol” OR DE “Serotonin Norepinephrine Reuptake Inhibitors” OR DE “Sertraline” OR DE “Sulpiride” OR DE “Tranylcypromine” OR DE “Trazodone” OR DE “Tricyclic Antidepressant Drugs” OR DE “Venlafaxine” OR DE “Zimeldine” OR DE “Psychotherapy” OR DE “Adlerian Psychotherapy” OR DE “Adolescent Psychotherapy” OR DE “Affirmative Therapy” OR DE “Analytical Psychotherapy” OR DE “Autogenic Training” OR DE “Behavior Therapy” OR DE “Brief Psychotherapy” OR DE “Brief Relational Therapy” OR DE “Child Psychotherapy” OR DE “Client Centered Therapy” OR DE “Cognitive Behavior Therapy” OR DE “Conversion Therapy” OR DE “Eclectic Psychotherapy” OR DE “Emotion Focused Therapy” OR DE “Existential Therapy” OR DE “Experiential Psychotherapy” OR DE “Expressive Psychotherapy” OR DE “Eye Movement Desensitization Therapy” OR DE “Feminist Therapy” OR DE “Geriatric Psychotherapy” OR DE “Gestalt Therapy” OR DE “Group Psychotherapy” OR DE “Guided Imagery” OR DE “Humanistic Psychotherapy” OR DE “Hypnotherapy” OR DE “Individual Psychotherapy” OR DE “Insight Therapy” OR DE “Integrative Psychotherapy” OR DE “Interpersonal Psychotherapy” OR DE “Logotherapy” OR DE “Narrative Therapy” OR DE “Network Therapy” OR DE “Persuasion Therapy” OR DE “Primal Therapy” OR DE “Psychoanalysis” OR DE “Psychodrama” OR DE “Psychodynamic Psychotherapy” OR DE “Psychotherapeutic Counseling” OR DE “Rational Emotive Behavior Therapy” OR DE “Reality Therapy” OR DE “Relationship Therapy” OR DE “Solution Focused Therapy” OR DE “Supportive Psychotherapy” OR DE “Transactional Analysis” OR DE “Exercise” OR DE “Aerobic Exercise” OR DE “Weightlifting” OR DE “Yoga” OR DE “Physical Therapy” OR DE “Rehabilitation” OR DE “Hypericum Perforatum” OR DE “Health Education” OR DE “Stress” OR DE “Psychological Stress” OR DE “Stress and Coping Measures” OR DE “Electroconvulsive Shock Therapy” OR DE “Continuum of Care” OR DE “Transcranial Magnetic Stimulation” OR TI ( bupropion OR citalopram OR desvenlafaxine OR duloxetine OR fluoxetine OR escitalopram OR levomilnacipran OR mirtazapine OR nefazodone OR paroxetine OR sertraline OR trazodone OR venlafaxine OR vilazodone OR vortioxetine OR amitriptyline OR Desipramine OR Doxepin OR Imipramine OR Protriptyline OR Trimipramine OR nortriptyline OR Amoxapine OR antidepressants OR antidepressant OR “psychotherapy” OR “behavior therapy” OR “behavioral therapy” OR “cognitive therapy” OR “problem solving therapy” OR “psychodynamic therapy” OR mindfulness OR “acceptance and commitment therapy” OR “reminiscence therapy” OR “behavioral action” OR “compassion-based therapy” OR exercise OR psychosocial OR “cardiac rehabilitation” OR “physical therapy” OR hypericum OR “st john’s wort” OR “saint john’s wort” OR education OR psychoeducation OR stress OR “collaborative care” OR “Transcranial Magnetic Stimulation” OR “S-Adenosylmethionine” OR “fish oil” OR “fish oils” OR “fatty acid” OR “fatty acids” OR “omega 3”) OR AB ( bupropion OR citalopram OR desvenlafaxine OR duloxetine OR fluoxetine OR escitalopram OR levomilnacipran OR mirtazapine OR nefazodone OR paroxetine OR sertraline OR trazodone OR venlafaxine OR vilazodone OR vortioxetine OR amitriptyline OR Desipramine OR Doxepin OR Imipramine OR Protriptyline OR Trimipramine OR nortriptyline OR Amoxapine OR antidepressants OR antidepressant OR “psychotherapy” OR “behavior therapy” OR “behavioral therapy” OR “cognitive therapy” OR “problem solving therapy” OR “psychodynamic therapy” OR mindfulness OR “acceptance and commitment therapy” OR “reminiscence therapy” OR “behavioral action” OR “compassion-based therapy” OR exercise OR psychosocial OR “cardiac rehabilitation” OR “physical therapy” OR hypericum OR “st john’s wort” OR “saint john’s wort” OR education OR psychoeducation OR stress OR “collaborative care” OR “Transcranial Magnetic Stimulation” OR “S-Adenosylmethionine” OR “fish oil” OR “fish oils” OR “fatty acid” OR “fatty acids” OR “omega 3”)
#5 | ZC “treatment outcome/clinical trial” OR DE “Clinical Trials” OR TI (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials) OR AB (randomized OR randomised OR randomization OR randomisation OR randomly OR trial OR groups OR trials) OR ZC “meta analysis” OR ZC “systematic review” OR DE “Meta Analysis” OR TI (OR “meta-analysis” OR “meta-analyses” OR “systematic review” OR “systematic reviews) OR AB (OR “meta-analysis” OR “meta-analyses” OR “systematic review” OR “systematic reviews) AND (ZZ “journal article”)
#6 | (S1 OR S2) AND S3 AND S4 AND S5 Limits: English, 2003 – present, Human

## CINAHL Search Strategy (August 15, 2017)

### KQ 1

Search Number | Search String
#1 | (MH “Myocardial Infarction+”) OR TI ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” ) OR AB ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” )
#2 | (MH “Acute Coronary Syndrome”) OR TI “Acute Coronary Syndrome” OR AB “Acute Coronary Syndrome”
#3 | (MH “Affective Disorders+”) OR TI ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” ) OR AB ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” )
#4 | (MH “Depression+/DI”) OR (MH “Health Screening+”) OR (MH “Questionnaires+”) OR (MH “Interviews+”) OR (MH “Psychometrics”) OR (MH “Psychological Tests+”) OR (MH “Behavior Rating Scales”) OR (MH “Scales”) OR (MH “Beck Depression Inventory, Revised Edition”) OR (MH “Center for Epidemiological Studies Depression Scale”) OR (MH “Geriatric Depression Scale”) OR TI (questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR inventory OR BDI OR “beck depression inventory” OR CES-D20 OR CES-D10 OR “Center for Epidemiologic Studies Depression Scale” OR HADS OR HADS-D OR “Hospital Anxiety and Depression Scale” OR PHQ-9 OR PHQ-8 OR “Patient Health Questionnaire” OR “Zung SDS” OR “Zung Self-Rating Depression Scale” OR “Zung Self Assessment Depression Scale” OR “symptom checklist 20” OR “Hopkins symptom checklist” OR “Kessler psychological distress scale” OR “distress questionnaire 5” OR “geriatric depression scale” OR “gds-15” OR “primary care rapid evaluation of mental disorders” OR “prime-md” OR “duke anxiety and depression scale” OR “inventory to diagnose depression” OR “world health organization 5” OR “who-5” OR “Quick Inventory of Depressive Symptomatology” OR promis OR “patient reported outcomes measurement information system”) OR AB (questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR inventory OR BDI OR “beck depression inventory” OR CES-D20 OR CES-D10 OR “Center for Epidemiologic Studies Depression Scale” OR HADS OR HADS-D OR “Hospital Anxiety and Depression Scale” OR PHQ-9 OR PHQ-8 OR “Patient Health Questionnaire” OR “Zung SDS” OR “Zung Self-Rating Depression Scale” OR “Zung Self Assessment Depression Scale” OR “symptom checklist 20” OR “Hopkins symptom checklist” OR “Kessler psychological distress scale” OR “distress questionnaire 5” OR “geriatric depression scale” OR “gds-15” OR OR “primary care rapid evaluation of mental disorders” OR “prime-md” OR “duke anxiety and depression scale” OR “inventory to diagnose depression” OR “world health organization 5” OR “who-5” OR “Quick Inventory of Depressive Symptomatology” OR promis OR “patient reported outcomes measurement information system”)
#5 | MH “Systematic Review” OR MH “Meta Analysis” OR TI (“systematic review” OR “systematic reviews” OR “meta-analysis” OR “meta-analyses”) OR AB (“systematic review” OR “systematic reviews” OR “meta-analysis” OR “meta-analyses”) OR (MH “Retrospective Design”) OR (MH “Empirical Research”) OR (MH “Nonexperimental Studies+”) OR TI (“evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study”) OR AB (“evaluation study” OR evaluation studies OR “intervention study” OR “intervention studies” OR “case-control” OR cohort OR longitudinal OR longitudinally OR prospective OR prospectively OR retrospective OR “comparative study”) AND (ZT “journal article”)
#6 | (S1 OR S2) AND S3 AND S4 AND S5

### KQ 2

Search Number | Search String
#1 | (MH “Myocardial Infarction+”) OR TI ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” ) OR AB ( “myocardial infarction” OR “myocardial infarct” OR “myocardial infarctions” OR “heart infarction” OR “heart infarct” OR “heart infarctions” OR “heart attack” OR “heart attacks” )
#2 | (MH “Acute Coronary Syndrome”) OR TI “Acute Coronary Syndrome” OR AB “Acute Coronary Syndrome”
#3 | (MH “Affective Disorders+”) OR TI ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” ) OR AB ( depression OR depressive OR “mood disorder” OR “mood disorders” OR “psychiatric disorder” OR “psychiatric disorders” )
#4 | (MH “Depression+/TH”) OR (MH “Antidepressive Agents+”) OR (MH “Psychotherapy+”) OR (MH “Exercise+”) OR (MH “Physical Therapy+”) OR (MH “Rehabilitation, Cardiac+”) OR (MH “St. John’s Wort”) OR (MH “Health Education+”) OR (MH “Adaptation, Psychological+”) OR (MH “Stress Management”) OR (MH “Electroconvulsive Therapy”) OR (MH “Continuity of Patient Care+”) OR (MH “Fish Oils+”) OR (MH “Transcranial Magnetic Stimulation”) OR (MH “S-Adenosylmethionine”) OR TI ( bupropion OR citalopram OR desvenlafaxine OR duloxetine OR fluoxetine OR escitalopram OR levomilnacipran OR mirtazapine OR nefazodone OR paroxetine OR sertraline OR trazodone OR venlafaxine OR vilazodone OR vortioxetine OR amitriptyline OR Desipramine OR Doxepin OR Imipramine OR Protriptyline OR Trimipramine OR nortriptyline OR Amoxapine OR antidepressants OR antidepressant OR “psychotherapy” OR “behavior therapy” OR “behavioral therapy” OR “cognitive therapy” OR “problem solving therapy” OR “psychodynamic therapy” OR mindfulness OR “acceptance and commitment therapy” OR “reminiscence therapy” OR “behavioral action” OR “compassion-based therapy” OR exercise OR psychosocial OR “cardiac rehabilitation” OR “physical therapy” OR hypericum OR “st john’s wort” OR “saint john’s wort” OR education OR psychoeducation OR stress OR “collaborative care” OR “Transcranial Magnetic Stimulation” OR “S-Adenosylmethionine” OR “fish oil” OR “fish oils” OR “fatty acid” OR “fatty acids” OR “omega 3”) OR AB ( bupropion OR citalopram OR desvenlafaxine OR duloxetine OR fluoxetine OR escitalopram OR levomilnacipran OR mirtazapine OR nefazodone OR paroxetine OR sertraline OR trazodone OR venlafaxine OR vilazodone OR vortioxetine OR amitriptyline OR Desipramine OR Doxepin OR Imipramine OR Protriptyline OR Trimipramine OR nortriptyline OR Amoxapine OR antidepressants OR antidepressant OR “psychotherapy” OR “behavior therapy” OR “behavioral therapy” OR “cognitive therapy” OR “problem solving therapy” OR “psychodynamic therapy” OR mindfulness OR “acceptance and commitment therapy” OR “reminiscence therapy” OR “behavioral action” OR “compassion-based therapy” OR exercise OR psychosocial OR “cardiac rehabilitation” OR “physical therapy” OR hypericum OR “st john’s wort” OR “saint john’s wort” OR education OR psychoeducation OR stress OR “collaborative care” OR “Transcranial Magnetic Stimulation” OR “S-Adenosylmethionine” OR “fish oil” OR “fish oils” OR “fatty acid” OR “fatty acids” OR “omega 3”)
#5 | (ZT “randomized controlled trial”) OR MH “Randomized Controlled Trials” OR TI (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomized” OR “randomization” OR “randomization” OR “placebo” OR “randomly” OR “trial” OR “groups”) OR AB (“randomized controlled trial” OR “controlled clinical trial” OR “randomized” OR “randomized” OR “randomization” OR “randomization” OR “placebo” OR “randomly” OR “trial” OR “groups”) OR MH “Systematic Review” OR MH “Meta Analysis” OR TI (“systematic review” OR “systematic reviews” OR “meta-analysis” OR “meta-analyses”) OR AB (“systematic review” OR “systematic reviews” OR “meta-analysis” OR “meta-analyses”) OR (MH “Empirical Research”) AND (ZT “journal article”)
#6 | (S1 OR S2) AND S3 AND S4 AND S5

## Gray Literature Search

### ClinicalTrials.gov (May 9, 2017)

Search Number | Search String
Search Terms | (“Myocardial Infarction” OR “myocardial infarctions” OR “heart attack” OR “heart attacks” OR “Acute Coronary Syndrome”) AND (Depression OR “Mental Disorders” OR depressive OR “mood disorder” OR “mood disorders” OR psychiatric)
Recruitment | Completed studies

Total number of results: 64