# Appendix A FDA Status and Warnings for Drugs Included in This Review

Appendix Table A1 Second-generation antidepressant medications that are FDA approved for treatment of major depressive disorder^1^

Drug | FDA-Labeled Indication for Depressive Disorders | Additional Warnings and Cautions relevant to Adults with Cardiovascular disease
Warnings: All antidepressants have a black box warning for increased risk of suicidal thinking and behavior in children, adolescents and adults 18–24 years of age. There is also a risk of withdrawal symptoms if discontinued abruptly. Other risks of SSRI/SNRIs: bleeding, fracture, narrow angle glaucoma, serotonin syndrome, sexual dysfunction, syndrome of inappropriate antidiuretic hormone secretion (SIADH). Many antidepressants have cautions for use in patients with angle-closure glaucoma, bipolar disorder, pregnancy in 3^rd^ trimester, or seizure disorders.
Atypical antidepressants
Bupropion | Yes | Contraindicated in seizure disorders or eating disorders
Mirtazapine | Yes | –
Nefazodone | Yes | Hepatic failure
Trazodone | Yes | –
Vilazodone^2^ | Yes | –
Vortioxetine^3^ | Yes | –
SSRIs
Citalopram | Yes | Bradycardia, Ventricular arrhythmias, QT prolongation, Recent MI, CHF; Reduce dose if age >60
Fluoxetine | Yes | Bradycardia, Ventricular arrhythmias, QT prolongation, Recent MI, CHF
Escitalopram | Yes | Bradycardia, Ventricular arrhythmias, QT prolongation, Recent MI, CHF
Paroxetine | Yes | –
Sertraline | Yes | –
SNRIs
Desvenlafaxine | Yes | Cardiovascular disease
Duloxetine | Yes | Hypertension
Levomilnacipran^4^ | Yes | Cerebrovascular disease, Cardiovascular disease, Hypertension, ≥ Stage 3 CKD
Venlafaxine | Yes | Heart failure, recent MI

Abbreviations: MI=myocardial infarction; CHF=congestive heart failure; CKD=chronic kidney disease; SIADH=syndrome of inappropriate antidiuretic hormone secretion; SSRIs=selective serotonin reuptake inhibitors; SNRIs=serotonin–norepinephrine reuptake inhibitors

Appendix Table A2 Atypical antipsychotics that are FDA approved for treatment of major depressive disorder^1^

Drug | FDA-Labeled Indication for Depressive Disorders | Additional Warnings and Cautions relevant to Adults with Cardiovascular disease
Warnings: Black box warning for increased risk of suicidal thinking and behavior in children, adolescents and adults 18–24 years of age (Aripiprazole and Quetiapine). Black box warning for increased risk of death in elderly patients with dementia-related psychosis. Other risks related to atypical antipsychotics: altered cardiac conduction (prolonged QTc), blood dyscrasia, increased stroke in dementia related psychosis, CNS depression, anticholinergic effect, dyslipidemia, hyperlipidemia, aspiration, extrapyramidal symptoms, neuroleptic malignant syndrome, orthostatic hypotension, pathologic gambling, impaired temperature regulation, weight gain and metabolic side effects.
Aripiprazole^5^ | Yes, as an adjunct with an antidepressant | FDA safety alert: uncontrollable urges to gamble, binge eat, shop or have sex. Other risks: akathisia, restlessness, sedation, headache, nausea and vomiting
Olanzapine^6^ | For bipolar depression and treatment resistant depression, only in combination with fluoxetine | FDA safety alert: DRESS (drug reaction with eosinophilia and systemic symptoms) FDA black box: delirium/sedation syndrome with long acting injection (likely not relevant to use in depression) Other risks: akathisia, sedation, dizziness, headache, increased prolactin Risk of suicidal thoughts and behavior but does not have black box.
Quetiapine^7^ | Yes, as an adjunct with an antidepressant | Other risks: sedation, hypertension, cataracts, hypothyroidism, headache, tachycardia, increased prolactin

Abbreviations: CNS=central nervous system; QTc=corrected QT interval

Appendix Table A3 Tricyclic antidepressants that are FDA approved for treatment of major depressive disorder^1^

Drug | FDA-Labeled Indication for Depressive Disorders | Additional Warnings and Cautions relevant to Adults with Cardiovascular disease
Warnings: All antidepressants have a black box warning for increased risk of suicidal thinking and behavior in children, adolescents and adults 18–24 years of age. Contraindicated for use with or within 14 days of concomitant monoamine oxidase inhibitor (MAOI) therapy. Tricyclic antidepressants are contraindicated during the acute recovery period following a myocardial infarction. There is also a risk of withdrawal symptoms if discontinued abruptly. Tricyclic antidepressants should be used with caution in patients with a history of cardiovascular disease due to the risk of conduction abnormalities. Other risks related to tricyclic antidepressants include altered cardiac conduction (prolonged QTc), orthostatic hypotension, anticholinergic effects (including but not limited to constipation, urinary retention and blurred vision) and CNS depression including sedation. Tricyclic antidepressants should be used with caution in individuals with bipolar disorder, the elderly and those with hepatic impairment or a history of seizures.
Amitryptiline^8–9^ | Yes | –
Amoxapine^10–11^ | Yes | History of neuroleptic malignant syndrome, high environmental temperatures
Desipramine^12–13^ | Yes | –
Doxepin | Yes | –
Imipramine^14–15^ | Yes | –
Nortryptiline^16–17^ | Yes | –
Protryptiline^18–19^ | Yes | –
Trimipramine | Yes | –

Abbreviations: CNS=central nervous system; MAOI=monoamine oxidase inhibitor; QTc=corrected QT interval

## Notes to Appendix Tables A1, A2, and A3

1 Depression: Medicines to Help You. FDA office of women’s Health. http://www.fda.gov/downloads/ForConsumers/ByAudience/ForWomen/FreePublications/UCM182083.pdf

2 Vilazodone: Drug Information. http://www.uptodate.com/contents/vilazodone-drug-information?source=search_result&search=vilazodone&selectedTitle=1%7E13#F11595949

3 Vorioxetine: Drug Information. http://www.uptodate.com/contents/vortioxetine-drug-information?source=search_result&search=vortioxetine&selectedTitle=1%7E8

4 Levomilnacipran: Drug Information. http://www.uptodate.com/contents/levomilnacipran-drug-information?source=search_result&search=levomilnacipran&selectedTitle=1%7E6

5 Aripiprazole: Drug Information. http://www.uptodate.com/contents/aripiprazole-short-acting-oral-and-injectable-and-long-acting-injectable-abilify-maintena-drug-information?source=search_result&search=abilify&selectedTitle=1%7E62

6 Olanzapine: Drug Information. http://www.uptodate.com/contents/olanzapine-drug-information?source=search_result&search=zyprexa&selectedTitle=1%7E121

7 Quetiapine: Drug Information. http://www.uptodate.com/contents/quetiapine-drug-information?source=search_result&search=quetiapine&selectedTitle=1%7E105

8 Amitriptyline: Product Information: amitriptyline hcl oral tablets, amitriptyline hcl oral tablets. Vintage Pharmaceuticals, LLC, Huntsville, AL, 2006.

9 Amitriptyline: Drug Information. http://www.uptodate.com/contents/amitriptyline-drug-information?source=search_result&search=Amitriptyline&selectedTitle=1~139

10 Amoxapine: Product Information: amoxapine oral tablets, amoxapine oral tablets. Watson Pharma, Inc. (per DailyMed), Parsippany, NJ, 2014.

11 Amoxapine: Drug Information. http://www.uptodate.com/contents/amoxapine-drug-information?source=search_result&search=amoxapine&selectedTitle=1~8

12 Desipramine: Product Information: NORPRAMIN(R) oral tablets, desipramine HCl oral tablets. Sanofi-Aventis U.S. LLC (per FDA), Bridgewater, NJ, 2014

13 Desipramine: Drug Information. http://www.uptodate.com/contents/desipramine-drug-information?source=search_result&search=Desipramine&selectedTitle=1~74

14 Imipramine: Product Information: Tofranil-PM(TM) oral capsules, imipramine pamoate oral capsules. Mallinckrodt Inc. (per FDA), Hazelwood, MO, 2014.

15 Imipramine: Drug Information. http://www.uptodate.com/contents/imipramine-drug-information?source=search_result&search=Imipramine&selectedTitle=1~76

16 Nortriptyline: Product Information: Pamelor(TM) oral solution, nortriptyline HCl oral solution. Mallinckrodt Inc. (per FDA), Hazelwood, MO, 2014.

17 Nortriptyline: Drug Information. http://www.uptodate.com/contents/nortriptyline-drug-information?source=search_result&search=Nortriptyline&selectedTitle=1~92

18 Protriptyline: Product Information: VIVACTIL(R) film-coated tablets, protriptyline HCl film-coated tablets. Teva Pharmaceuticals USA, Inc. (per FDA), Horsham, PA, 2014.

19 Protriptyline: Drug Information. http://www.uptodate.com/contents/protriptyline-drug-information?source=search_result&search=Protriptyline&selectedTitle=1~19