# Acronyms and Abbreviations

Acronym: Definition
ACS: Acute coronary syndrome
AUC: Area under the curve
BDI: Beck Depression Inventory
BDI-II: Beck Depression Inventory, 2^nd^ edition
CBT: Cognitive behavioral therapy
CDSR: Cochrane Database of Systematic Reviews
CI: Confidence interval
CKD: Chronic kidney disease
CODIACS: Comparison of Depression Interventions after Acute Coronary Syndrome
COPES: Coronary Patients Evaluation Study
DISH: Depression Interview and Structured Hamilton
DSM-III: Diagnostic and Statistical Manual of Mental Disorders, 3^rd^ edition
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition
DSM-IV-TR: Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition, Text Revision
ENRICHD: Enhancing Recovery in Coronary Heart Disease study
GAD: Generalized anxiety disorder
GDS: Geriatric Depression Scale
GI: Gastrointestinal
HADS: Hospital Anxiety and Depression Scale
HDRS: Hamilton Depression Rating Scale
HR: Hazard ratio
HRSD: Hamilton Rating Scale for Depression
ICD-10: International Classification of Disease, 10^th^ edition
LPSS: Low perceived social support
MACE: Major adverse cardiac events
MBCT: Mindfulness-based cognitive therapy
MCS: Mental component summary
MDD: Major depressive disorder
MI: Myocardial infarction
MIND-IT: Myocardial Infarction and Depression-Intervention Trial
MINI: Mini International Neuropsychiatric Interview
NPV: Negative predictive value
OR: Odds ratio
PHQ: Patient Health Questionnaire
PPV: Positive predictive value
PROMIS: Patient-Reported Outcomes Measurement Information System
PRIME-MD: Primary Care Evaluation of Mental Disorders
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QUADAS-2: Quality Assessment of Diagnostic Accuracy Studies, 2^nd^ edition
ROC: Receiver operating characteristic
RR: Risk ratio
SCID-I/NP: Structured Clinical Interview for DSM-IV-TR Axis I Disorders, Non-Patient edition
SD: Standard deviation
SE: Standard error
SNRI: Serotonin-norepinephrine reuptake inhibitor
SSRI: Selective serotonin reuptake inhibitor