# Summary and Discussion

The results of the comparative effectiveness review of four types of radiotherapy (IMRT, 3DCRT, 2DRT, and proton beam therapy) are summarized in the following table. A small body of randomized, controlled trials is accompanied by a larger body of poor quality observational, nonrandomized studies. Study quality was assessed according to principles described in a reference guide for conducting comparative effectiveness reviews produced by AHRQ.156 The observational studies reviewed here are clinically diverse with respect to patient characteristics and treatment setting, creating uncertainty about whether results should be attributed to confounding rather than treatment differences. Details were often lacking among observational studies about patient characteristics and treatments and it was not clear for any study whether well-done multivariable analyses were performed to adjust for differences.

The main conclusion is that there is moderate evidence that IMRT, compared with 3DCRT, reduces late xerostomia and improves quality of life, particularly quality of life domains most related to xerostomia. This conclusion is based primarily on the consistency of large differences favoring IMRT in 6 observational studies. A recent randomized, controlled trial also found results supporting this conclusion, but full details of this study are unavailable, so it is difficult to assess its quality and contribution to the overall body of evidence. There was also moderate evidence that IMRT, compared with 2DRT, reduces late xerostomia and improves quality of life domains related to xerostomia. However, the comparison of IMRT versus 2DRT relies greatly on inferences drawn from evidence comparing IMRT versus 3DCRT, which demonstrate the relationship between radiation dose conformality in the treatment of head and neck cancers and reduction in the frequency of late xerostomia. Inconsistent and nonsignificant results were observed between IMRT and comparators on other adverse events, overall quality of life, tumor control, and survival outcomes. Thus, the evidence is insufficient to support conclusions in these areas.

Key Question | Level of Evidence | Conclusion
1. What is the comparative effectiveness of IMRT, 3DCRT, 2DRT and proton beam therapy regarding quality of life and adverse events? | | - There were 38 comparative studies. Of these, four were randomized, controlled trials. One randomized, controlled trial could not be clearly rated because a manuscript was unavailable, one was rated fair and two were rated poor due to lack of intention-to-treat analysis.; - The remaining 34 studies were observational, with significant flaws such as lack of comparable groups at baseline; comparing radiotherapy technologies at different points in time, that is, the study arms were not contemporaneous; and poorly done multivariable analyses.
1a. IMRT versus 3DCRT | Moderate (late xerostomia, quality of life) Insufficient (other outcomes) | - One randomized, controlled trial presented at a conference showed a large advantage for IMRT in the frequency of late xerostomia grade 2 or higher. The risk difference was 35 percentage points with a 95% confidence interval between 12.6 and 55.5 percentage points.; - Six observational studies favored IMRT. Of the five studies that reported frequencies, the reported range of differences is 7 to 79 percentage points.; - Quality of life was reported in three observational studies and generally favored IMRT, although not all domains measured were statistically significant. Significant advantages for IMRT included these domains: dry mouth, sticky saliva, taste/smell, fatigue and feeling ill.; - Acute xerostomia, acute mucositis, late mucositis, acute dysphagia, late skin toxicity, late osteoradionecrosis and bone toxicity were reported in some and typically favored IMRT but differences were not consistently statistically significant. Among studies of acute skin toxicity neither the size of the difference nor the direction was consistent.
1b. 3DCRT versus 2DRT | Insufficient (all outcomes) | - Four studies reported on late xerostomia with a range of differences between 3DCRT and 2DRT of 15 to 48 percentage points, except one study that favored 2DRT by 10 percentage points. Only one result was statistically significant.; - One study compared quality of life outcomes between 3DCRT and 2DRT but did not report a statistical comparison.; - Acute xerostomia, acute mucositis, late mucositis, acute dysphagia, acute skin toxicity, late skin toxicity, and late osteoradionecrosis and bone toxicity were reported in a few studies and differences between 3DCRT and 2DRT were small and not statistically significant, not exceeding a difference of 9 percentage points.; - The available literature is of insufficient quantity and quality and to ascertain whether there are differences in quality of life or adverse events between 3DCRT and 2DRT.
1c. IMRT versus 2DRT | Moderate (late xerostomia, quality of life) Insufficient (other outcomes) | - Nine studies reported on late xerostomia, and eight were statistically significant in favor of IMRT. Among the studies that reported frequency, the range of differences between IMRT and 2DRT was 43 to 62 percentage points..; - Quality of life was reported in one randomized, controlled trial and two observational studies and generally favored IMRT although not all domains measured were statistically significant. Domains significantly favoring IMRT included dry mouth and sticky saliva.; - Indirect evidence from the comparison of IMRT vs. 3DCRT shows that greater conformality of radiation reduces late xerostomia and improves quality of life. Thus, inference from comparison of IMRT vs. 3DCRT, provides additional support for this conclusion.; - Acute and late mucositis, acute and late dysphagia, acute and late skin toxicity, and late osteoradionecrosis and bone toxicity were reported in some studies. Few studies reported significant results. These tended to be small studies or the 2DRT data were from an earlier time period than IMRT.
1d. Proton beam versus other techniques | Insufficient | - There were no comparative studies.
2. What is the comparative effectiveness of IMRT, 3DCRT, 2DRT and proton beam therapy regarding tumor control and patient survival? | | - The body of evidence was the same as for Question 1.
2a. IMRT versus 3DRCT | Insufficient (all outcomes) | - In the single randomized, controlled trial presented at a conference, the sample size is too small and followup is too short to ascertain any differences in tumor control or survival.; - Of the seven comparative observational studies reporting tumor control, none reported statistically significant differences between IMRT and 3DCRT.; - Of seven comparative studies reporting patient survival, one reported a statistically significant result; the difference was in the slight-to-moderate range and favors IMRT.; - No conclusions on tumor control or survival can be drawn from the body of evidence comparing IMRT versus 3DCRT.
2b. 3DCRT versus 2DRT | Insufficient (all outcomes) | - Of the eight comparative studies reporting tumor control, one reported a statistically significant difference in favor of 3DCRT. This randomized, controlled trial reported a large difference in tumor control at one year but did not report intent-to-treat analysis.; - Of seven comparative studies reporting patient survival, none reported a statistically significant result.; - No conclusions on tumor control or survival can be drawn from the body of evidence comparing 3DCRT versus 2DRT.
2c. IMRT versus 2DRT | Insufficient (all outcomes) | - Of the six comparative observational studies reporting tumor control, none reported a statistically significant difference.; - Of seven comparative observational studies reporting patient survival, one reported a large, statistically significant result in favor of IMRT.; - No conclusions on tumor control or survival can be drawn from the body of evidence comparing IMRT versus 2DRT.
2d. Proton beam versus other techniques | Insufficient | - There were no comparative studies.
3. Patient and tumor characteristics affecting outcomes | Insufficient | - No comparative studies addressed this issue.
4. Radiotherapy/physician characteristics affecting outcomes | Insufficient | - No studies addressed this issue.

Compared to either 3DCRT or 2DRT, IMRT produces a more conformal dose distribution and a steeper dose gradient between the tumor target and adjacent uninvolved tissues or organs at risk. Dose distribution is considered an intermediate outcome, which may be related to health outcomes, but by itself does not establish the comparative effectiveness of different radiotherapy techniques. It was hypothesized that these technical differences would result in improved tumor control while reducing the incidence and severity of radiation toxicities, particularly in head and neck cancer patients treated with IMRT compared to 3DCRT or 2DRT.157,158

In using IMRT to treat head and neck cancer patients, theoretical dose delivery advantages must be translated into improved therapeutic outcomes. There is potential to introduce small errors or inconsistencies at each step in the process of inverse treatment planning and its ultimate delivery. Thus, accurate delineation of the tumor, surrounding areas at risk for subclinical disease, and normal tissues or organs at risk for radiation toxicities rely on the accuracy of computed tomography. Subsequent conversion of the physician-prescribed doses to a radiotherapy plan by one of several available inverse treatment planning systems also is subject to variability based on the type of system used.159 Because there are often clear discrepancies between the prescribed dose and the amount of radiation ultimately delivered to a specific patient, treatment planning studies are not sufficient to demonstrate the comparative effectiveness of different radiotherapy modalities. Furthermore, differences among patients in susceptibilities to specific adverse events, for example xerostomia, preclude the use of dose planning studies to compare techniques.160 Comparative evidence on clinical outcomes is necessary to establish that the technical advantages of IMRT do indeed benefit patients, not only by decreasing xerostomia, but also by achieving similar or improved tumor control and survival.

The capability of IMRT to deliver steep dose gradients around a tumor site may present a risk as well as potential benefit.161 Because the dose gradient (i.e., the difference in dose between the tumor and adjacent healthy areas) is greater for IMRT than for other modalities, patient positioning becomes critical. If the planned dose does not align with the tumor contour and other anatomic attributes of the patient, the planned and actual dose may diverge substantially. It is possible for part of the tumor to receive a much lower dose than needed if it inadvertently receives the dose intended for the adjacent healthy tissue and vice versa. A few millimeters of margin is built into the treatment plan (i.e., planning target volume) to account for this, but it may not be uniformly the right amount and can detract from the precision of IMRT. Tumor shrinkage and differences in patient habitus due to weight loss during treatment also may alter the relation of the planned dose distribution to the intended target.157,158

Most of the studies in this review were based on the results of patients treated at academic medical centers. However, an informal survey estimates that 30 to 60 percent of all cancer patients in the U.S. are treated with IMRT.159 Whether similar results will be achieved as the technology diffuses to less-experienced settings162 has not been addressed in the comparative studies available for this review.