# Results

## Search Results

Of 2,679 records found in the electronic literature search, 354 articles were retrieved for further screening. Thirty-eight articles describing comparative studies were abstracted,28,30,32–36,39,40,41,63–90 (Appendix D) in addition to 51 single -arm studies relating to IMRT,29,31,37,38,91–137 18 single-arm 3DCRT studies, 42,138–154(Appendix E) and one proton beam therapy single -arm study.155 This report will focus primarily on comparative studies. Of the 38 comparative studies, five were three-arm designs, so the total number of comparisons is 48. Interventions in comparative studies included IMRT, 3DCRT and 2DRT; none included proton beam therapy.

## Organization of Results Chapter

- Comment on clinical diversity of the available evidence
- Synthesis of evidence across all four Key Questions, organized by specific comparison
- Summary of randomized, controlled trial evidence
- Summary of comparative study evidence base, emphasizing quantity of evidence by outcome and study quality concerns
- Applicability of evidence base
- Detailed description of evidence for Key Questions 1 and 2 organized by comparison, proceeding by site and setting
  - IMRT single -arm studies summary
  - 3DCRT single-arm studies summary
- Discussion of Key Question 3
- Discussion of Key Question 4
- Conclusions

A comprehensive listing of Abbreviations used throughout this review appears at the end of the document.

### The Available Evidence is Clinically Diverse

The available evidence presented two main methodological challenges: clinical diversity and confounding. The evidence is highly diverse with respect to patient and treatment characteristics, both within and among studies. Clinical diversity refers to the mixing of patient groups with various characteristics such as different tumor histologies, tumor sites, stage of disease, age and treatment setting. Clinical diversity can be in measured or unmeasured characteristics and may reflect otherwise unmeasured prognostic factors. Clinical diversity contributes to confounding, which occurs when imbalances distort the estimates of treatment effects, leading to false conclusions. The distortion can overestimate or underestimate the presence, size and direction of the true treatment effect.

To provide greater clarity in synthesis of the evidence, this review sorts evidence first by comparison, then by site and by setting. This review emphasizes studies that selected participants with a single tumor site (such as nasopharyngeal, oropharyngeal, nasal cavity/paranasal sinuses, unknown primary and laryngeal), and a single setting (e.g., primary radiotherapy, primary radiotherapy plus concurrent chemotherapy, postoperative radiotherapy, etc.). Studies that included participants with mixed sites or settings are considered weaker in design.

### Synthesis of Evidence Across all Key Questions

Tables 4–6 provide a synthesis of the body of evidence according to the AHRQ/GRADE framework for the three main comparisons. There were no comparative studies involving proton beam therapy, therefore no table addresses this intervention.

Table 4 Overall grade of strength of evidence, IMRT vs. 3DCRT

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Overall Grade/Conclusion
1. What is the comparative effectiveness of IMRT and 3DCRT regarding quality of life and adverse events? | Among 14 comparative studies addressing IMRT and 3DCRT, one was a randomized, controlled trials, the other 13 were observational, of which five were prospective designs. | The single randomized, controlled trial was presented at a conference and is not yet published, making rating of quality difficult. All other studies were rated as poor quality by the USPSTF framework and had an inherent risk of bias. Risk of bias in observational studies was due to:; - uncertainty whether groups were comparable,; - uncertainty regarding blinding of outcome assessors; - noncontemporaneous treatment groups or unclear, and; - lack of well-done multivariable analyses to adjust for confounding. | Consistent results were observed for two outcomes:; - late xerostomia (7 studies); and; - quality of life (3 studies), particularly domains most related to xerostomia; Large statistically significant or nonsignificant differences favored IMRT. Although observational studies are not well designed to control for bias and confounding, it is unlikely that there was systematic imbalance of patients with a lower susceptibility to xerostomia in the IMRT groups. Susceptibility is common in the head/neck cancer population due to cancer site, prior and concurrent treatments, and sometimes older age and chronic medications Inconsistent results were observed for these outcomes:; - acute xerostomia;; - acute mucositis;; - late mucositis;; - acute dysphagia;; - late skin toxicity; and; - late osteoradionecrosis and bone toxicity.; Results for these outcomes were reported in some studies and typically favored IMRT but differences were not consistently statistically significant. Among studies of acute skin toxicity neither the size of the difference nor the direction was consistent. | Direct evidence was available for all outcomes considered under this Key Question. There is direct evidence on late xerostomia from 7 studies | The single RCT shows a risk difference of grade 2 or higher xerostomia at 1 year of 35 percentage points with a 95% confidence interval from 12.6 to 55.4 percentage points. For observational studies, confidence intervals were not reported. Although we could not arrive at a pooled estimate or a confidence interval for the effect, the consistent direction and moderate-to-large differences favoring IMRT for frequency of late xerostomia, suggests a real effect. | The strength of the body of evidence is moderate for IMRT reducing late xerostomia and improving quality of life domains related to xerostomia compared with 3DCRT. One randomized, controlled trial and six observational studies found consistent results favoring IMRT. It was not possible to create a pooled effect estimate with a confidence interval. The strength of evidence is insufficient to draw conclusions about the comparative effects of IMRT and 3DCRT for other adverse events. In the future, well-designed studies may clarify the magnitude of effect for late xerostomia and quality of life, as well as whether there are between-group differences on other outcomes.
2. What is the comparative effectiveness of IMRT and 3DCRT regarding tumor control and patient survival? | Key Question 1 and Key Question 2 were addressed by a common set of studies. | The single randomized, controlled trial was presented at a conference and is not yet published, making rating of study quality difficult. Sample size is too small and followup is too short to ascertain any differences in tumor control or survival. All other studies were rated as poor quality by the USPSTF framework and therefore had an inherent risk of bias. Moreover, estimating between-group differences in disease-specific and overall survival is more complex than for adverse events. Observational studies can only be informative if there is detailed information about long-term losses to followup and well-done multivariable adjustment for confounding. | The evidence does not show consistently significant between-group differences for patient survival and tumor control. Of eight comparative studies reporting patient survival, one reported a statistically significant result; the difference was in the moderate range and favored IMRT Of the eight comparative studies reporting tumor control, none reported statistically significant differences between IMRT and 3DCRT. | Direct evidence is available for overall survival. Tumor control measures are intermediate outcomes, and are informative to the extent that they predict differences in disease-specific or overall survival. | Confidence intervals around observed treatment effects were not reported. Direction of effect cannot be determined. | The strength of the body of evidence is insufficient for tumor control and patient survival. No conclusions on tumor control or survival can be drawn from the body of evidence comparing IMRT versus 3DCRT. In the future, well-designed studies may clarify whether there are between-group differences on these outcomes.
3. Patient and tumor characteristics affecting outcomes | No comparative studies addressed this Key Question. | NA | NA | NA | NA | The strength of evidence is insufficient, thus no conclusions can be reached.
4. Radiotherapy or physician characteristics affecting outcomes | No comparative studies addressed this Key Question. | NA | NA | NA | NA | The strength of evidence is insufficient, thus no conclusions can be reached.

Abbreviations: NA: not applicable; RCT: randomized, controlled trial

Table 5 Overall grade of strength of evidence, 3DCRT vs. 2DRT

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Overall Grade/Conclusion
1. What is the comparative effectiveness of 3DCRT and 2DRT regarding quality of life and adverse events? | Among 12 comparative studies addressing 3DCRT and 2DRT, one was an RCT and 11 were observational, including three prospective designs. | High risk of bias was observed throughout this set of studies. All were rated as poor quality by the USPSTF framework.Risk of bias was due to:; - uncertainty whether groups were comparable,; - uncertainty whether outcome assessors were blinded,; - noncontemporaneous treatment groups or unclear, and; - lack of well-done multivariable analyses to adjust for confounding among observational studies and; - no intention-to-treat analysis in the RCT. | No consistent results were observed. Among four studies reporting on late xerostomia, one reported a large statistically significant difference; all others were either nonsignificant or of unclear significance. One study favored 2DRT by 10 percentage points; the others favored 3DCRT by 15 to 48 percentage points. Inconsistent results were observed for these outcomes:; - acute xerostomia;; - acute mucositis;; - late mucositis;; - acute dysphagia;; - acute skin toxicity;; - late skin toxicity; and; - late osteoradionecrosis and bone toxicity.; Results for these outcomes were reported in a few studies. Differences between 3DCRT and 2DRT were small and not statistically significant, not exceeding a difference of 9 percentage points. One study compared quality of life outcomes between 3DCRT and 2DRT but did not report a statistical comparison. | Direct evidence was available for all outcomes considered under this Key Question. | Confidence intervals around observed treatment effects were not reported. Direction of effect cannot be determined. | The strength of evidence is insufficient to draw conclusions about the comparative adverse events or quality of life associated with 3DCRT and 2DRT.
2. What is the comparative effectiveness of 3DCRT and 2DRT regarding tumor control and patient survival? | Key Question 1 and Key Question 2 were addressed by a common set of studies. | As these are the same studies considered for Key Question 1, the risk of bias is high, as noted above. All studies were rated as poor quality by the USPSTF framework and therefore had an inherent risk of bias. Moreover, estimating between-group differences in disease-specific and overall survival is more complex than for adverse events. Observational studies can only be informative if there is detailed information about long-term losses to followup and well-done multivariable adjustment for confounding. | The evidence does not show consistently significant between-group differences for patient survival and tumor control. Of the eight comparative studies reporting tumor control, one reported a statistically significant difference in favor of 3DCRT. This RCT reported a large difference in tumor control at one year but did not report intent-to-treat analysis. Other differences were nonsignificant and/or negligible to moderate in size. Of seven comparative studies reporting patient survival, none reported a statistically significant result. | Direct evidence is available for disease-specific and overall survival. Tumor control measures are intermediate outcomes, and are informative to the extent that they predict differences in disease-specific or overall survival. | Confidence intervals around observed treatment effects were not reported. Direction of effect cannot be determined. | The strength of the body of evidence is insufficient for tumor control and patient survival. No conclusions on tumor control or survival can be drawn from the body of evidence comparing 3DCRT versus 2DRT.
3. Patient and tumor characteristics affecting outcomes | No comparative studies addressed this Key Question. | NA | NA | NA | NA | The strength of evidence is insufficient, thus no conclusions can be reached.
4. Radiotherapy or physician characteristics affecting outcomes | No comparative studies addressed this Key Question. | NA | NA | NA | NA | The strength of evidence is insufficient, thus no conclusions can be reached.

Abbreviations: NA: not applicable; RCT: randomized, controlled trial

Table 6 Overall grade of strength of evidence, IMRT vs. 2DRT

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Overall Grade/Conclusion
1. What is the comparative effectiveness of IMRT and 2DRT regarding quality of life and adverse events? | Among 22 comparative studies addressing IMRT and 2DRT, 2 were RCTs, and 20 were observational, of which 5 were prospective designs. | A high risk of bias was observed throughout this set of studies. One RCT was rated as fair, while all other studies were rated as poor by the USPSTF framework. Risk of bias was due to:; - uncertainty re: comparable groups; - uncertainty re: blinding of outcome assessors noncontemp- oraneous treatment groups or unclear,; - lack of well-done multivariable analyses to adjust for confounding among observational studies and; - no ITT analysis in one RCT | Consistent results were observed for two outcomes:; - quality of life (3 studies); and; - late xerostomia (8 of 9 studies), particularly domains most related to xerostomia; Statistically significant or otherwise moderate to large differences favored IMRT. Although the observational studies are not well designed to control for bias and confounding, it is unlikely that there was systematic imbalance of patients with a lower susceptibility to xerostomia in the IMRT groups. Susceptibility to xerostomia is common in the head/neck cancer population due to cancer site and prior and concurrent treatments, and sometimes due to older age and chronic medications Inconsistent results were observed for these outcomes:; - acute xerostomia;; - acute mucositis;; - late mucositis;; - acute dysphagia;; - late dysphagia; - acute skin toxicity;; - late skin toxicity; and; - late osteoradionecrosis and bone toxicity.; Some of the strongest results were also found in studies with substantial methodological weaknesses. Of six comparative studies reporting patient survival, one reported a statistically significant result; the difference was large and favored IMRT. Of the five comparative studies reporting tumor control, none reported statistically significant differences between IMRT and 2DRT. | Although direct evidence was available for all outcomes considered under this Key Question, complementary evidence from the comparison between IMRT and 3DCRT provides strong but indirect support for conclusions. | Confidence intervals around observed treatment effects were not reported. Although we could not arrive at a pooled estimate of the effect or a confidence interval for the effect, the consistent direction and moderate-to-large differences. | The strength of the body of evidence is moderate for IMRT reducing late xerostomia and improving quality of life domains related to xerostomia compared with 2DRT. The direct evidence reviewed on IMRT vs. 2DRT, although of limited quality, suggests a true effect in favor of IMRT. Indirect evidence, inference from comparison of IMRT vs. 3DCRT, provides additional support for this conclusion. The advantage of IMRT over 3DCRT is due to greater conformality of radiation delivery. Similarly, IMRT is inferred to be superior to 2DRT because 2DRT is less conformal than 3DCRT. The strength of evidence is insufficient to draw conclusions about the comparative impact of IMRT and 2DRT for other adverse events.
2. What is the comparative effectiveness of IMRT and 2DRT regarding tumor control and patient survival? | Key Question 1 and Key Question 2 were addressed by a common set of studies. | As these are the same studies considered for Key Question 1, the risk of bias is high, as noted above. Except for one fair quality randomized trial, all studies were rated as poor quality by the USPSTF framework and therefore had an inherent risk of bias. Moreover, estimating between-group differences in disease-specific and overall survival is more complex than for adverse events. Observational studies can only be informative if there is detailed information about long-term losses to followup and well-done multivariable adjustment for confounding. | The evidence does not show consistently significant between-group differences for patient survival and tumor control. Of six comparative studies reporting patient survival, one reported a statistically significant result; the difference was large and favored IMRT. Of five comparative studies reporting tumor control, none reported statistically significant differences between IMRT and 2DRT. | Direct evidence is available for overall survival. Tumor control measures are intermediate outcomes, and are informative to the extent that they predict differences in disease-specific or overall survival. | Confidence intervals around observed treatment effects were not reported. Direction of effect cannot be determined. | The strength of the body of evidence is insufficient for tumor control and patient survival.. No conclusions on tumor control or survival can be drawn from the body of evidence comparing IMRT versus 2DRT.
3. Patient and tumor characteristics affecting outcomes | No comparative studies addressed this Key Question. | NA | NA | NA | NA | The strength of evidence is insufficient, thus no conclusions can be reached.
4. Radiotherapy or physician characteristics affecting outcomes | No comparative studies addressed this Key Question. | NA | NA | NA | NA | The strength of evidence is insufficient, thus no conclusions can be reached.

Abbreviations: ITT: intention to treat ; NA: not applicable; RCT: randomized, controlled trial

### IMRT Versus 3DCRT

Key Question 1: What is the comparative effectiveness of IMRT and 3DCRT regarding adverse events and quality of life?

The strength of the body of evidence showing IMRT reducing late xerostomia and improving quality of life domains related to xerostomia compared with 3DCRT was graded as moderate. One randomized, controlled trial88 presented at a conference showed a large advantage for IMRT in the frequency of late xerostomia grade 2 or higher. That randomized, controlled trial was presented in a conference proceeding, but is not yet published. Since this trial has not yet been published in full manuscript form, its quality is rated as uncertain, as we lack sufficient details about its methods to clearly evaluateit. In addition, six observational studies found large statistically significant or moderate nonsignificant differences favoring IMRT.33,34,71,79,81,83 All of the observational studies were of low quality; however, the reduction is unlikely the result of bias, as susceptibility to xerostomia is common in the head and neck cancer population and it is unlikely that between-group imbalances account for results. Thus, the evidence consistently shows that IMRT reduces the frequency of late xerostomia. Three observational studies32–34 reported quality-of-life outcomes and all favored IMRT, especially in domains related to late xerostomia.

The strength of evidence is insufficient to draw conclusions about the comparative effects of IMRT and 3DCRT for other adverse events. One randomized, controlled trial88 of uncertain quality presented at a conference was available and the quality of observational studies is poor, and no strongly consistent results are reported.

Key Question 2: What is the comparative effectiveness of IMRT and 3DCRT regarding tumor control and patient survival?

No conclusions on tumor control or survival can be drawn from the body of evidence comparing IMRT versus 3DCRT. The strength of the body of evidence for tumor control and patient survival is insufficient. Estimating between-group differences in disease-specific and overall survival is complex and requires greater controls for confounding and bias.

Key Question 3: Patient and tumor characteristics affecting outcomes.

Key Question 4: Radiotherapy/physician characteristics affecting outcomes.

The strength of evidence is insufficient as no comparative studies addressed these key questions. Therefore, no conclusions can be reached.

### 3DCRT Versus 2DRT

Key Question 1: What is the comparative effectiveness of 3DCRT and 2DRT regarding adverse events and quality of life?

The strength of evidence is insufficient to draw conclusions about the comparative adverse events or quality of life associated with 3DCRT and 2DRT. The studies are of poor quality and the results are inconsistent.

Key Question 2: What is the comparative effectiveness of 3DCRT and 2DRT regarding tumor control and patient survival?

No conclusions on tumor control or survival can be drawn from the body of evidence comparing 3DCRT versus 2DRT. The strength of the body of evidence for tumor control and patient survival is insufficient.

Key Question 3: Patient and tumor characteristics affecting outcomes.

Key Question 4: Radiotherapy/physician characteristics affecting outcomes.

The strength of evidence is insufficient as no comparative studies addressed these key questions. Therefore, no conclusions can be reached.

### IMRT Versus 2DRT

Key Question 1: What is the comparative effectiveness of IMRT and 2DRT regarding adverse events and quality of life?

The strength of the body of evidence is moderate for IMRT reducing late xerostomia and improving quality of life domains related to quality of life compared with 2DRT. The direct evidence reviewed on IMRT versus 2DRT, although of limited quality, suggests a true effect in favor of IMRT. Indirect evidence, inference from comparison of IMRT versus 3DCRT, provides additional support for this conclusion. The advantage of IMRT over 3DCRT is due to greater conformality of radiation delivery. Similarly, IMRT is inferred to be superior to 2DRT, because 2DRT is less conformal than 3DCRT.

The strength of evidence is insufficient to draw conclusions about the comparative effects of IMRT and 2DRT for other adverse events. The quality of available studies is poor and no strongly consistent results are reported.

Key Question 2: What is the comparative effectiveness of IMRT and 2DRT regarding tumor control and patient survival?

No conclusions on tumor control or survival can be drawn from the body of evidence comparing IMRT versus 2DRT. The strength of the body of evidence for tumor control and patient survival is insufficient.

Key Question 3: Patient and tumor characteristics affecting outcomes.

Key Question 4: Radiotherapy/physician characteristics affecting outcomes.

The strength of evidence is insufficient as no comparative studies addressed these key questions. Therefore, no conclusions can be reached.

### Proton Beam Therapy Versus Other Techniques

The strength of evidence is insufficient as no comparative studies addressed any of the key questions. Therefore, no conclusions can be reached regarding the comparative effectiveness of proton beam therapy.

### Summary of the Randomized, Controlled Trial Evidence

As shown in Table 7, four head-to-head randomized trials of IMRT, 3DCRT, and 2DRT have been published.28,41,85,88 Three were studies of patients with nasopharyngeal cancer, while one selected patients with oropharyngeal or hypopharyngeal cancer. The most recent randomized trial, designated PARSPORT, was reported by Nutting et al.88 at the 2009 annual meeting of the American Society of Clinical Oncology. Detailed slides from this unpublished study were available for review. Studies by Kim et al.41 and Pow et al.28 selected only patients with stage I/II disease and the Wu et al.85 study selected only patients with stage III/IV. The proportion of patients with stage III/IV disease included by Nutting et al.88 was 77 percent. Neither Kam et al.41 nor Wu et al.85 formally met study selection criteria, because patients were given a mix of radiotherapy modalities. They are presented in this review due to the limited number of randomized trials, otherwise. Kam et al. 41 compared primary IMRT and primary 2DRT, but both groups included some patients who did and did not receive intracavitary brachytherapy (ICBT). Wu et al.85 split radiotherapy in the treatment group between early course 2DRT and late course 3DCRT, while the control group received only 2DRT. All patients in both groups received split chemotherapy.

Table 7 Head-to-head randomized trials of IMRT, 3DCRT, and 2DRT for nasopharyngeal cancer

Study | Patients | Treatment | Control | Randomization Method | Outcomes | ITT?
Nutting et al. 2009[88] | 84, OPH/HYP | Primary or postoperative IMRT ± preRT chemotherapy | Primary or postoperative 3DCRT ± preRT chemotherapy | Centralized | Xerostomia, dysphagia, mucositis, skin, mandible, locoregional control, overall survival, quality of life (not included in conference presentation), salivary flow (not included in conference presentation) | Unclear
Kam et al. 2007[41] | 56, stage I/II NPC | Primary IMRT ± intracavitary brachytherapy | Primary 2DRT ± intracavitary brachytherapy | Centralized | Xerostomia, salivary flow | Yes
Pow et al. 2006[28] | 45, stage I/II NPC | Primary IMRT | Primary 2DRT | Unclear | Quality of life, salivary flow | No
Wu et al. 2005[85] | 96, stage III/IV NPC | Primary 2DRT/3DCRT + split chemotherapy | Primary 2DRT + split chemotherapy | Random draw from 20 numbers (treatment – odd, control – even) | Mucositis, local control, overall survival | Unclear

Abbreviations: HYP: hypopharynx; ITT: intention to treat; NPC: nasopharyngeal cancer; OPH: oropharyngral

### Summary of the Comparative Study Evidence Base

The 38 comparative studies collectively included 5,061 participants. By comparison type, 14 comparisons involved IMRT versus 3DCRT, 12 involved 3DCRT versus 2DCRT and 22 involved IMRT versus 2DRT. None of the comparative studies addressed proton beam therapy.

Quality of study methods among these 38 comparative studies is summarized in Appendix Table C3. About three-fifths of studies were retrospective designs. Twenty-nine studies enrolled patient groups that were initially not comparable or of unclear comparability. More than three-fifths of studies either used historical controls or did not specify whether treatments were given in the same time period. Because treatment approaches often evolve over time, such historical comparisons may not be relevant to strategies presently in use. Only the Kam et al.41 trial used a clearly random method for allocating patients to treatment groups. Of the other trials, Pow et al.28 did not describe the randomization process in any detail and Wu et al.85 noted a method that may have been biased. Two randomized trials41,88 used intention-to-treat analysis, one did not,28 and it was unclear for the fourth.85

Of the 34 nonrandomized studies, two33,75 allocated patients based on equipment availability or physician preference, one study81 based allocation on a waiting list, and two30,69 studies based allocation on risk to sensitive areas. Outcome measures were generally valid and reliable, but only one study28 stated that outcome assessors were blinded to treatment assignment. Sixteen studies did not conduct a multivariable analysis. None of the described multivariable analyses could be rated as well conducted: 21 were either not done or clearly not well done and for 13, it is unclear if they were well done.

Using the USPSTF rating system, one88 of these studies could not be clearly rated as a journal manuscript is not yet available, one41 was rated as fair quality, and the remaining 36 studies were rated as poor quality. Of particular concern is the common finding of noncomparable groups or uncertain comparability and complete lack of clearly well-conducted multivariable analyses to adjust for potential confounders.

### Applicability of the Evidence Base

The evidence appears to apply to a primarily middle-aged population with advanced head and neck cancer. Included studies were generally conducted at academic medical centers. Regarding study populations, the percentage of females in most studies was between 10 and 40 percent. Median age was in the 40s or 50s in all but five studies, consistent with ages when incidence of head and neck cancer increases considerably. One study enrolled pediatric patients with nasopharyngeal cancer, while the age ranges for the rest were quite close to 40 to 60 years. Table 8 shows how many studies enrolled different ranges of percentages for patients with stage III/IV disease. More studies included a large majority (≥75 percent) of patients with stage III/IV than any other category in this distribution. Nearly one-quarter of studies were very clinically diverse with respect to disease stage (25–74 percent stage III/IV). Three studies did not report stage information.

Table 8 Number of comparative studies reporting ranges of percentages of participants in American Joint Committee on Cancer stage III or IV

% Stage III or IV | Not Reported | 0–24% | 25–49% | 50–74% | 75–100%
No. of studies | 3 | 5 | 5 | 4 | 21

Prescribed dose (Table 9) was not reported in four studies. Eight studies gave a single value for prescribed dose for all patients or all patients in a given treatment group, ranging from 66 Gy to 75 Gy. In the 26 studies reporting a range of prescribed dose values, the minimum was at least 60 Gy in most studies and more than 70 Gy in most.

Table 9 Number of comparative studies reporting different minimum and maximum prescribed doses

Range of Prescribed Dose Among 26 of 38 Comparative Studies | Minimum ≤49 Gy | Minimum 50–59 Gy | Minimum ≥60 Gy | Maximum ? Gy | Maximum ≤69 Gy | Maximum 70–74 Gy | Maximum ≥75 Gy
No. of studies | 3 | 7 | 16 | 2 | 1 | 13 | 10

Gy: Gray

## Key Question 1. What is the comparative effectiveness of IMRT, 3DCRT, 2DRT, and proton beam therapy regarding adverse events and quality of life? AND Key Question 2. What is the comparative effectiveness of IMRT, 3DCRT, 2DRT, and proton beam therapy regarding tumor control and patient survival?

### Comparative Studies, IMRT Versus 3DCRT

#### Overview

Of the three main comparisons that are addressed here, IMRT versus 3DCRT is the most relevant. Both take advantage of three-dimensional target delineation using CT or MRI and have been in frequent use in the past decade. In contrast, 2DRT relies on two-dimensional target localization and is currently little-used. This section compares IMRT and 3DCRT regarding evidence about quality of life, adverse events, tumor control and patient survival.

Fourteen studies provide comparative evidence on IMRT and 3DCRT. Table 10 shows that two comparisons included individuals with nasopharyngeal cancer, four with oropharyngeal patients, one with nasal cavity/paranasal sinus cancer and 6 with a mix of tumor sites. One randomized, controlled trial has addressed this comparison and the other 13 studies were observational designs. Seven studies were prospective designs and seven were retrospective.

Table 10 IMRT vs. 3DCRT: Summary of study design, quality, and key outcomes

Site | Studies | n | RCT | Prospective Observational | Assessor Blinded | Groups Comparable | Treatments in same time period | Well-done multi- variable analysis/intention- to-treat | USPSTF Good/Fair
NPC | 2 | 288 | 0 | 1 | 0 | 1 | 1 | 0 | 0/0
OPH | 4 | 410 | 1 | 1 | 0 | 1 | 2 | 1 | 0/0
PNS | 1 | 68 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
UNP | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
LAR | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
MIX | 7 | 986 | 0 | 5 | 0 | 0 | 3 | 0 | 0/0
Total | 14 | 1752 | 1 | 7 | 0 | 2 | 6 | 1 | 0/0

Outcome | Total No. studies | Large (>15 pctg pts) IMRT-3DCRT difference | | | | Moderate (6–15 pctg pts) IMRT-3DCRT difference | | | | Small (0–5 pctg pts) IMRT-3DCRT difference | | | | Unquantifiable IMRT-3DCRT difference
Outcome | Total No. studies | No. Studies | Sig | NS | p NR | No. Studies | Sig | NS | p NR | No. Studies | Sig | NS | P NR | No. Studies | Sig | NS | p NR
Acute xerostomia | 4 | 2 | 2+ | | | | | | | 2 | | 1? | 1+
Late xerostomia | 7 | 4 | 4+ | | | 2 | | 2+ | | | | | | 1 | | | 1+
Acute mucositis | 6 | 1 | | 1+ | | 1 | | 1+ | | 4 | | 3+ | 1−
Late mucositis | 2 | | | | | 1 | | 1− | | 1 | | | 1+
Acute dysphagia | 2 | | | | | 1 | 1+ | | | 1 | | | 1?
Late dysphagia | 2 | | | | | 2 | 1− | 1−
Acute skin toxicity | 5 | 2 | 2+ | | | 1 | 1− | | | 2 | | | 1− 1?
Late skin toxicity | 3 | | | | | 1 | | 1+ | | 2 | | | 2+
Acute osteoradionecrosis/bone toxicity | 0
Late osteoradionecrosis/bone toxicity | 2 | | | | | 1 | | | 1+ | 1 | | 1−
Tumor control^*^ | 8 | 2 | | 2+ | | 2 | | 2+ | | 5 | | 3+ 1? 1−
Patient survival^*^ | 8 | 1 | | 1+ | | 4 | 1+ | 1+ 1− | 1+ | 4 | | 3+ 1?

+: favors IMRT; −: favors 3DCRT; ?: unclear which group is favored;

* Columns to the right may not sum to the total, because some studies reported more than one outcome for tumor control or patient survival, e.g., disease-specific survival and overall survival.

Abbreviations: NR: not reported; NS: not significant; pctg: percentage; pts: patients; RCT: randomized, controlled trial; sig: significant; USPSTF: U.S. Preventive Services Task force;

The quality of all 13 observational studies was rated poor by USPSTF criteria, while the randomized, controlled trial could not be clearly rated as a manuscript is not available. None of these studies reported using blinded outcome assessors or well-done multivariable analyses to control for confounding. It was clear in two studies that groups were comparable on baseline characteristics and co-interventions. Six studies made clear that groups were treated during the same time period, while the periods were either unclear or different in the rest. Lack of concurrent treatment groups could mean that patients treated in an earlier era with 3DCRT may have received therapy that does not represent more current methods of 3DCRT. Furthermore, co-interventions given during different eras may have divergent effects.

To conclude that outcomes differ between treatments, there should be predominantly moderate to large between-group differences favoring one treatment consistently. This level of consistency is needed to counteract uncertainty created by the risk of bias. Consistent results favoring IMRT were observed on later xerostomia and quality of life domains related to xerostomia.

Adverse event comparisons that report numerical differences in incidence are presented graphically in Appendix C, Figures C1–C9. Four studies found large (greater than 15 percentage points) significant differences favoring IMRT in the frequency of grade 2 or worse late xerostomia.34,81,83,88 Two other studies found moderate differences between groups favoring IMRT on late xerostomia.71,79 Vergeer et al. 34 found significant advantages for IMRT on most subscales of the EORTC QLQ-C30 and EORTC H&N-35 quality of life instruments (Table 11). Among the former’s subscales were global health, fatigue and appetite loss and among the latter’s subscales were dry mouth, pain, swallowing, social eating, teeth, opening mouth, and feeling ill. Fang et al.33 observed a significant advantage for IMRT on the EORTC QLQ-C30 global health and fatigue subscales and on the EORTC H&N-35 dry mouth, taste/smell and feeling ill subscales. The smallest of three studies reporting quality of life data found no significant between-group differences on either instrument, but large, nonsignificant differences in favor of IMRT were seen on the EORTC QLQ-C30 pain and appetite loss subscales and the EORTC H&N-35 speech, social eating, teeth and opening mouth subscales.

Table 11 IMRT vs. 3DCRT: Summary of quality of life data

Study | EORTC QLQ-C30 (# domains) | | | EORTC H&N-35 (# domains) | | | SF-36 (# domains) | | | Other (HNCI, HNQOL) (# domains)
Study | + | NS | — | + | NS | — | + | NS | — | + | NS | —
Fang et al. 2007[32] | | 15 | | | 12
Fang et al. 2008[33] | 2 | 12 | | 3 | 12
Vergeer et al. 2008[34] | 8 | 7 | | 9 | 3

KEY:

+ statistically significant difference in favor of more conformal modality (listed first in comparison in 1^st^ column)

NS difference not statistically significant

— statistically significant difference in favor of less conformal modality (listed second in comparison in 1^st^ column)

* Between-group difference in total score, adjusted for baseline score.

It is unlikely that there was systematic imbalance of patients with a lower susceptibility to late xerostomia in the IMRT groups among observational studies. A susceptibility to xerostomia is common in the head and neck cancer population due to cancer site and prior and co-interventions and sometimes due to older age and chronic medications. Thus, the consistency of results suggests a treatment effect favoring IMRT.

Inconsistent results were observed for these outcomes: acute xerostomia; acute mucositis; late mucositis; acute dysphagia; late skin toxicity; and late osteoradionecrosis and bone toxicity. Results for these outcomes were reported in some studies and typically favored IMRT, but differences were not consistently moderate to large in size or statistically significant. Among studies of acute skin toxicity, neither the size of the difference nor the direction was consistent.

Among eight studies reporting tumor control outcomes, moderate to large differences favoring IMRT were not consistently reported. None of these results were statistically significant. Similarly inconsistent results were found among eight studies with evidence on patient survival. One study reported a statistically significant result; the difference was in the moderate range and favored IMRT. Compared with assessing a local adverse event like xerostomia, estimating between-group differences in disease-specific and overall survival is more complex and requires greater detail about long-term losses to followup and assurances that multivariable adjustment for confounding is well done.

Detailed results are presented in the following sections by site, then setting. Studies that were homogeneous by site and setting are described before clinically diverse studies. Recall that treatment setting refers to the presence and timing of combinations of these modalities for a given patient: surgery, radiation therapy, and chemotherapy. A homogeneous treatment setting within a study could mean that all patients in that study received, for example, postoperative radiotherapy with concurrent chemotherapy.

IMRT Versus 3DCRT: Nasopharyngeal Cancer, Mixed Settings. A retrospective study from 2007 by Fang and colleagues32 (Table 12) included patients treated for nasopharyngeal cancer by primary radiotherapy with or without chemotherapy, although the timing of chemotherapy was unclear. Four treatment arms were included: 2DRT, 2DRT plus 3DCRT boost, 3DCRT, and IMRT. The second arm is not discussed here due to mixing of radiotherapy modalities, so this study is considered a three-arm design in this review. The key outcomes were QOL (EORTC QLQ-C30 and EORTC QLQ-H&N35) and late xerostomia. Multivariable analyses were conducted on global QOL and xerostomia, but they separated radiotherapy technique into two groups: 2DRT combined with 2DRT plus 3DCRT boost and 3DCRT combined with IMRT. Thus, these multivariable analyses are off-topic for the purposes of this review.

Table 12 IMRT vs. 3DCRT: Summary of studies of nasopharyngeal cancer, mixed settings

Study | Setting | Outcome | n | Univariate p value | Multi-variable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Fang et al. 2007[32] | Primary RT ± chemotherapy with unclear timing | Quality of life | 85 | [underlined: 24–36 mo, EORTC QLQ-C30] NS for all domains: Global Health, Physical Function, Role Function, Emotional Function, Cognitive Function, Social Function, Fatigue, Nausea/Vomiting, Pain, Dyspnea, Insomnia, Appetite Loss, Constipation, Diarrhea, Financial Difficulties [underlined: EORTC QLQ-H&N35] NS for all domains: Pain, Swallowing, Taste/smell, Social eating, Social contract, Sexuality, Teeth, Opening mouth, Dry mouth, Sticky saliva, Coughing, Feeling ill | | Retrospective | Yes | Yes | Off-topic | Poor
Fang et al. 2008[33] | Primary RT ± concurrent chemotherapy | Quality of life | 203 | [underlined: Post-RT/3/12/24 mo. EORTC QLQ-C30] Global health, 3 mo. IMRT+ <.05 (all other F/U NS) Fatigue, 3 mo. IMRT- <.05 (all other F/U NS) All other domains, all F/U NS: Physical Function, Role Function, Social Function, Nausea/Vomiting, Pain, Dyspnea, Insomnia, Appetite Loss, Constipation, Diarrhea, Financial Difficulties, [underlined: EORTC QLQ-H&N35 Taste/Smell, 3 mo.] IMRT- <.05 (all other F/U NS) Dry Mouth, 3 mo. IMRT- <.05 (all other F/U NS) Feeling Ill, 3 mo. IMRT- <.05 (all other F/U NS) All other domains, all F/U NS: Pain, Swallowing, Social Eating, Social Contract, Sexuality, Teeth, Opening Mouth, Sticky Saliva, Coughing | | Prospective | Yes | Yes | Unclear | Poor
Fang et al. 2007[32] | | Xerostomia | 85 | [underlined: 24–36 mo, EORTC QLQ-H&N35] Dry Mouth item NS | | Retrospective | | | Off-topic
Fang et al. 2008[33] | | Xerostomia | | [underlined: Post-RT/3/12/24 mo, EORTC QLQ-H&N35] Dry Mouth item, 3 mo. IMRT- <.05 (all other F/U NS) | | Prospective | | | Unclear
Fang et al. 2008[33] | | Locoregional control | 203 | 3 yr., Δ+1, NS | NS | | | | Unclear
Fang et al. 2008[33] | | Overall survival | 203 | 3 yr., Δ+1, NS | NS | | | | Unclear

IMRT+: IMRT favored, IMRT−: IMRT not favored

IMRT and 2DRT groups were mostly similar with respect to median age (49, 51 years), percentage female (29 percent and 24 percent) and percentage in stage III/IV (48 percent and 49 percent). Group proportions of patients given more than 70.2 Gee were 54 percent and 58 percent. Lack of multivariable analyses comparing IMRT and 3DCRT was largely responsible for the USPSTF rating of poor. Univariate comparisons found no statistically significant differences between IMRT and 3DCRT on any domains from the two QOL scales, including the EORTC QLQ-H&N35 xerostomia domain. It would be unwise to interpret these data as evidence of similar QOL for IMRT and 3DCRT.

The only other study comparing IMRT with 3DCRT was reported by Fang et al.33 in 2008. This prospective study involved primary radiotherapy with or without chemotherapy. Groups appeared similar with regard to percentage of females (22 percent, 17 percent) and stage III/IV (53 percent, 56 percent), but IMRT has a lower percentage of individuals over age 60 (14 percent, 25 percent) and those with T4 tumors (11 percent, 25 percent). The prescribed dose was between 65 and 76 Gy for all patients. Treatments were allocated based on equipment availability and physician preference. It is unclear whether multivariable analyses were well done. Followup was conducted at 3, 12, and 24 months. Only isolated significant between-group differences were reported on the EORTC QLQ-C30 and EORTC QLQ-H&N35 QOL scales. Significant differences favoring IMRT were observed at three months on two QLQ-C30 domains (Global Health and Fatigue) and three QLQ-H&N35 domains (Taste/Smell, Dry Mouth, and Feeling Ill). Note the lower proportion of IMRT participants over age 60 or with T4 tumors. Differences were not statistically significant for any other followup points and all other domains. Also, no differences were found between groups on locoregional control or overall survival. Taking these results with those of the 2007 Fang et al.32 study, the relative effects of IMRT and 3DCRT are unclear with respect to QOL, xerostomia, tumor control, and patient survival.

IMRT Versus 3DCRT: Oropharyngeal Cancer, Primary Radiotherapy Plus Concurrent Chemotherapy. Rusthoven et al.83 reported on primary IMRT or 3DCRT with concurrent chemotherapy (Table 13). This nonrandomized study found a significantly lower frequency of late xerostomia and acute skin toxicity with IMRT, but nonsignificant differences for mucositis, locoregional control, disease-free survival and overall survival.

Table 13 IMRT vs. 3DCRT: Summary data, oropharyngeal cancer

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Rusthoven et al. 2008[83] | Primary RT + concurrent chemotherapy | Xerostomia | 87 | 6/12/18 mos., ≥ Gr 2, Δ−38/Δ−79/Δ−87, <.001 | | Retrospective | No | ? | Not done | Poor
Hodge et al. 2007[71] | Primary RT ± concurrent chemotherapy | Xerostomia | 195 | Late, Gr mod, Δ−7, NS | | Retrospective | Yes | Yes/No | Not done | Poor
Rades et al. 2007[81] | Postoperative RT ± concurrent chemotherapy | Xerostomia | 44 | Late, Gr 2–3, Δ−56, .037 | | Retrospective | Yes | Unclear | Not done | Poor
Nutting et al. 2009[88] | Primary or postoperative IMRT ± preRT chemotherapy | Xerostomia | 84 | Acute, Gr ≥ 2, Δ−20, .02 3/6/12/18 mos., Gr > 2, Δ−21/Δ−26/Δ−35/Δ−42, ≤.05 | | Prospective | Yes | Yes | Not applicable | Good
Nutting et al. 2009[88] | | Dysphagia | 84 | Acute, Gr ≥ 2, Δ−11, .05 Late, Gr ≥ 2, Δ−+7, NS | | | | | Not applicable
Rusthoven et al. 2008[83] | | Mucositis | 87 | Acute, ≥ Gr 3, Δ+3, p NR | | | | | Not done
Hodge et al. 2007[71] | | Mucositis | 195 | Acute, Gr 3, Δ−17, NS | | | | | Not done
Rades et al. 2007[81] | | Mucositis | 44 | Acute, Gr 2–3, Δ−4, p NR | | | | | Not done
Nutting et al. 2009[88] | | Mucositis | 84 | Acute, Gr ≥ 2, Δ−7, 0.18 Late, Gr ≥ 2, Δ+8, NS | | | | | Not applicable
Rusthoven et al. 2008[83] | | Skin toxicity | 87 | Acute, ≥ Gr 3, Δ−18, .002 | | | | | Not done
Rades et al. 2007[81] | | Skin toxicity | 44 | Acute, Gr 2–3, Δ+5, p NR Late, Gr 2–3, Δ−5, p NR | | | | | Not done
Nutting et al. 2009[88] | | Skin toxicity | 84 | Acute, Gr ≥ 2, Δ --17, .02 Late, Gr ≥ 2, Δ −7, NS | | | | | Not applicable
Nutting et al. 2009[88] | | Osteoradionecrosis or bone toxicity | 84 | Late, Gr ≥ 2, Δ −+1, NS
Rades et al. 2007[81] | | Local control | 44 | 2 yr. Δ+10, NS | NS | | | | Unclear
Rusthoven et al. 2008[83] | | Locoregional control | 87 | 4 yr. Δ+15, NS | .075 | | | | Unclear
Hodge et al. 2007[71] | | Locoregional control | 195 | 4 yr. Δ+18, p NR | | | | | Not done
Nutting et al. 2009[88] | | Locoregional control | 84 | 1 yr. Δ −0.7, NS | | | | | Not applicable
Rusthoven et al. 2008[83] | | Disease-free survival | 87 | 4 yr. Δ+18, NS | NS | | | | Unclear
Hodge et al. 2007[71] | | Disease-free survival | 195 | 4 yr. Δ+14, p NR | | | | | Not done
Rusthoven et al. 2008[83] | | Overall survival | 87 | 4 yr. Δ+17, NS | NS | | | | Unclear
Hodge et al. 2007[71] | | Overall survival | 195 | 4 yr. Δ+7, .02 | NS | | | | Unclear
Rades et al. 2007[81] | | Overall survival | 44 | 2 yr. Δ+6, NS | NS | | | | Unclear
Nutting et al. 2009[88] | | Overall survival | 84 | 1 yr. Δ+2.8, NS | | | | | Not applicable

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

Of the 87 patients with oropharyngeal cancer in the study,83 the percentage female by group was 12 percent and 9 percent; all had stage III or IV cancer; and the prescribed dose to the primary tumor was 66–70 Gy for 3DCRT and 70–72 Gy for IMRT, respectively. Patients treated with IMRT were significantly less likely to experience acute xerostomia (p<.001) or acute skin toxicities (p=.002). At 6 months, 12 months, and 18 months, the differences in percentages with grade 2 or higher xerostomia favoring IMRT were 38 points, 79 points, and 87 points, respectively. Enrollment in this study occurred between 1998 and 2007 and the article does not make clear whether the two groups accrued equally over this period. If 3DCRT patients accrued mainly in the early study period, the reported difference may be greater than with current modalities. The reported higher prescribed dose range for IMRT suggests that the observed between-group difference is credible. The rates of mucositis appeared similar between IMRT and 3DCRT; statistical significance was not reported.

Two tumor control outcomes (locoregional control and disease-free survival) and overall patient survival were reported. Between -group comparisons appeared to favor IMRT for all three outcomes at four years, but no statistically significant differences were detected, using either univariate or multivariable analyses.

IMRT Versus 3DCRT: Oropharyngeal Cancer, Mixed Setting. Three studies compared IMRT and 3DCRT in patients with oropharyngeal cancer with mixed settings. A randomized trial by Nutting et al.88 gave patients primary or postoperative radiotherapy with or without neoadjuvant chemotherapy. Of the two nonrandomized studies, Hodge et al.71 included two sets 3DCRT controls: one from the IMRT era and the other from an earlier era (Table 13). Rades et al.81 conducted a three -arm study, using postoperative radiotherapy with or without chemotherapy. Hodge et al.71 delivered primary radiotherapy to all patients and Rides et al.81 administered postoperative radiotherapy to all; both studies included a mix of patients who did and did not have concurrent chemotherapy.

The one-year rate of grade 2 or higher xerostomia was the primary outcome in the Nutting et al.88 randomized trial; IMRT resulted in a 35 percentage point advantage (p= .004). The 95 percent confidence interval around this risk difference is between 12.6 percentage points and 55.5 percentage points. Significant xerostomia results also favored IMRT in the acute period and at 3, 6, and 18 months. Nutting et al. 88 also reported significant advantages for IMRT in acute dysphagia and acute skin toxicity and nonsignificant results for late dysphagia, late skin toxicity, late bone toxicity, and both acute and late mucositis. Rades et al.81 observed a 56 percentage point reduction in the frequency of late grade 2–3 xerostomia (p=.037). Hodge et al.71 did not find a statistically significant reduction in late xerostomia. For other outcomes, between-group differences in the two nonrandomized studies were either not statistically significant (e.g., acute mucositis,71 local control,81 overall survival, 71 multivariable analysis81) or p values were not reported (e.g., acute mucositis,81 acute and late skin toxicity,81 locoregional control, 71 disease-specific survival71).

The mean age reported by Nutting et al.88 was 58 years, while n either nonrandomized study reported on patient age. Rades et al.81 does not report on gender distribution, while the sample selected by Nutting et al.88 was 28 percent female and in Hodge et al.,71 it was 5–29 percent female across treatment groups. The proportion of patients with stage III/IV disease included by Nutting et al.88 was 77 percent. In the Hodge study,71 the percentage of patients with stage III or IV disease was slightly lower in the IMRT group (86 percent) compared with the contemporaneous 3DCRT group (100%). Rades et al.81 also had fewer patients with more advanced stage disease in the IMRT group (at least 50 percent versus at least 65 percent). The prescribed primary tumor dose was 60–70 for both treatments in the Rades et al.81 study and 65 –70 for IMRT, and 60–78 for 3DCRT in the Hodge et al. study.71

Comparing outcomes of 3DCRT before and after the introduction of IMRT in Hodge et al.71 suggests 3DCRT may have improved over time. For example, four -year overall survival was 88 percent for IMRT, 81 percent for contemporaneous 3DCRT, and about 56 percent for pre-IMRT era 3DCRT, although IMRT was not a significant predictor of overall survival in a multivariable model that also included tumor stage. Fifty-six percent of IMRT patients had late xerostomia, compared 63 percent of 3DCRT patients treated during the same period (who also had a higher percentage of advanced cancer than either other group), and 67 percent of 3DCRT patients treated earlier. The statistical significance of differences in 3DCRT outcomes before and after the introduction of IMRT is not reported.

IMRT Versus 3DCRT: Nasal Cavity and Paranasal Sinuses, Mixed Settings. The study by Chen et al.67 was limited to patients with cancer of the nasal cavity/paranasal sinuses and compared IMRT versus 3DCRT on toxicities, tumor control and patient survival outcomes (Table 14). Of the 68 of the patients receiving IMRT or 3DCRT, 40 percent were women; the median age was 61; and more than 85 percent had Stage III or IV cancer. The prescribed dose to the primary tumor fell in a broader range for 3DCRT (50–73 Gy) than for IMRT (66–72 Gy). Patients varied in the timing of radiotherapy and in both use and timing of chemotherapy. The frequency of late mucositis and skin toxicity was similar for IMRT and 3DCRT, while osteoradionecrosis or bone toxicity occurred slightly less often in the IMRT group. However, no statistical tests were reported for these comparisons. At five years, local control was similar for IMRT and 3DCRT, while overall survival was higher in the 3DCRT group; the magnitude of the difference for disease-free survival was not reported. None of these three comparisons was statistically significant. These results could be confounded by a number of factors, including treatment timing and potential baseline differences between groups.

Table 14 IMRT vs. 3DCRT: Nasal cavity or paranasal cancer, mixed settings

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Chen et al. 2007[67] | Primary/preoperative/postoperative RT ± post-RT/concurrent chemotherapy | Mucositis | 68 | Late, ≥ Gr 3, Δ−3, p NR | | Retrospective | Unclear | No | Not done | Poor
Chen et al. 2007[67] | | Skin toxicity | 68 | Late, ≥ Gr 3, Δ−5, p NR | | | | | Not done
Chen et al. 2007[67] | | Osteoradionecrosis/bone toxicity | 68 | Late, ≥ Gr 3, Δ−7, p NR | | | | | Not done
Chen et al. 2007[67] | | Local control | 68 | 5 yr., Δ+3, NS | | | | | Not done
Chen et al. 2007[67] | | Disease-free survival | 68 | NS | | | | | Not done
Chen et al. 2007[67] | | Overall survival | 68 | 5 yr., Δ−10, NS | | | | | Not done

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

IMRT Versus 3DCRT: Mixed Tumor Sites, Primary Radiotherapy. Golen et al.69 compared IMRT and 3DCRT among mixed head and neck cancer patients with a single treatment setting: primary radiotherapy and no chemotherapy (Table 15). The groups were described as similar for the single reported outcome—xerostomia—but no statistics were given. The lack of multiple settings is a positive attribute of this study, but is offset by uncertainty about whether groups were comparable at baseline. Of the 40 patients in this study,69 28 percent were women and 40 percent had stage III or IV cancer; age was not reported. The primary tumor prescribed dose was 62–72 Gy. Group means for xerostomia were reported at 3, 6, 12, 18, 24, and 30 months, but no statistical tests were reported. The groups were described as similar in the study. No multivariable analyses were performed to account for possible confounding factors; and no other outcomes were reported.

Table 15 IMRT vs. 3DCRT: Summary data on primary radiotherapy for mixed tumor sites

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Golen et al. 2007[69] | Primary RT | Xerostomia | 40 | 3/6/12/18/24/30 months Group late Gr means presented at each F/U, but no statistical test results given, groups described as similar | | Retrospective | Unclear | Yes, but allocation based on whether 3DCRT would deliver higher dose to parotids | Not done | Poor

IMRT Versus 3DCRT: Mixed Tumor Sites, Mixed Settings. Six studies34,65,70,79,80,89 (Table 16) with mixed tumor sites and mixed settings compared outcomes of IMRT and 3DCRT. Most of the studies treated patients with primary or postoperative radiotherapy, with or without chemotherapy. Of a total of 946 subjects, the majority were male in four34,65,80,89 of the studies; one79 did not report gender; the median age was in the 50s in three studies and the 60s in one (two studies34,79 did not report age); and in three 34,65,80 of the studies, more than 60 percent of the patients had advanced cancer (stage III or IV). The prescribed dose to the primary tumor ranged from a minimum of 46 Gy to a maximum of 70 Gy; one study79 did not report dose.

Table 16 IMRT vs. 3DCRT: Summary data on mixed settings for mixed tumor sites

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Vergeer et al. 2008[34] | Primary/postoperative RT ± concurrent chemotherapy | Quality of life | 141 | [underlined: 1.5/6 mo EORTC QLQ-C30, ANOVA with linear (l) and quadratic (q, changing effect sizes over time) time analyses] Domains with statistically significant results: Global Health <.004-l, Role Function .042-l, Cognitive Function .033-l, Social Function <.001-l, Fatigue .026-l, Pain .042-q, Insomnia <.021-l, Appetite Loss .018-l Domains with NS results: Physical Function, Emotional Function, Nausea/Vomiting, Dyspnea, Constipation, Diarrhea, Financial Difficulties [underlined: 1.5/6 mo EORTC QLQ-H&N35] Domains with statistically significant results: Pain .03-l, .046- q; Swallowing .042-l, Social Eating .011-l, Sexuality .003-l, Teeth .015-l, Opening Mouth .026-q, Dry Mouth <.001-l, Sticky Saliva .001-l, Feeling Ill .0011-l Domains with NS results: Taste/Smell, Speech, Coughing | | Prospective | No | No | Not done | Poor
Marchal et al. 2004[79] | Primary/postoperative/repeat RT ± pre-RT/post-RT/concurrent chemotherapy | Xerostomia | 87 | Acute, ≥ Gr 2, Δ−1, p NR Late, ≥ Gr 2, Δ−8, .06 | | Prospective | Unclear | Yes | Not done | Poor
Palazzi et al. 2008[80] | Primary/postoperative RT ± concurrent ± pre-RT chemotherapy | Xerostomia | 137 | Acute, > Gr 2 | NS | Prospective | Unclear | No | Unclear | Poor
Vergeer et al. 2008[34] | | Xerostomia | 141 | Acute, Gr 2, Δ−17, .014 Late, Gr mod-sev, Δ−26, ≤ .001 Late mean xerostomia item from EORTC QLQ- H&N35, at 1.5/6/12 mo IMRT- ≤ .002 Late, ≥ Gr 2, IMRT- .002 | mod-sev, MV logistic regression adjusted OR (95% CI): 0.27 (0.13, 0.54) Gr 2–3, MV logistic regression adjusted OR (95% CI): 0.24 (0.12, 0.51) | | | | Unclear
Chao et al. 2001[65] | Primary/postoperative RT ± post-RT/concurrent chemotherapy | Salivary flow | 41 | 6 mos., stimulated whole salivary flow | NS | Prospective | Unclear | Yes | Unclear | Poor
Palazzi et al. 2008[80] | | Dysphagia | 137 | Acute, > Gr 2 | NS
Langendijk et al. 2009[89] | Primary/postoperative RT± chemotherapy with unclear timing | Dysphagia | 529 | Late, Gr 2–4, Δ+12, .043 | Not reported | Prospective | Unclear | Yes | No | Poor
Palazzi et al. 2008[80] | | Mucositis | 137 | Acute, > Gr 2 | NS
Vergeer et al. 2008[34] | | Mucositis | 141 | Acute, ≥ Gr 3, Δ−4 NS
Palazzi et al. 2008[80] | | Skin toxicity | 137 | Acute, > Gr 2 | NS
Vergeer et al. 2008[34] | | Skin toxicity | 141 | Acute, Gr 2, Δ+12, .03
Marchal et al. 2004[79] | | Disease- free survival | 87 | 1 yr., Δ+3, NS
Gomez et al. 2008[70] | Primary/postoperative RT ± chemotherapy with unclear timing | Disease- free survival | 42 | NS | Not entered | Retrospective | Unclear | Yes | Unclear | Poor
Marchal et al. 2004[79] | | Overall survival | 87 | 1 yr., Δ+3, NS
Gomez et al. 2008[70] | | Overall survival | 42 | NS | Not entered

Abbreviations: Δ: change; Gr: grade; mos.: months; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

Vergeer et al.34 reported on quality of life, using the validated EORTC QLQ −30. The IMRT group improved more than the 3DCRT group between 1.5 and 6 months after treatment for the following domains: global health; role, cognitive, and social function; fatigue; pain, insomnia; and appetite loss (all p<.05). Using the head and neck symptom-specific, validated EORTC QLQ-H&N35, also at 1.5 and 6 months, the IMRT group improved more than the 3DCRT group on the following domains: pain, swallowing, social eating, sexuality, teeth, opening mouth, dry mouth, sticky saliva, and feeling ill (all p<.05).

The IMRT group had statistically significantly fewer adverse events than the 3DCRT group. Frequency of xerostomia was similar or smaller for IMRT, but some results were statistically significant,34 while others were not, 79,80 using salivary flow proxy. 65 One study 89 found a significantly higher frequency of late dysphagia among IMRT patients. Frequency differences between IMRT-and 3DCRT -treated patients were not statistically significant for acute dysphagia80 and acute mucositis; 34,80 the results for acute skin toxicity were mixed. 34,80 The differences between treatment groups were not statistically significant for the only other outcomes reported: disease-free (at one year79 or time not specified 70) and overall survival (at one year79 or time not specified 70).

### Comparative Studies, 3DCRT Versus 2DRT

#### Overview

In the progression of development of new radiotherapy techniques used to treat head and neck cancer, 2DRT is the oldest included in this review; it was followed by 3DCRT and later IMRT. The previous section compared IMRT and 3DCRT, the two more recent techniques. This section compares the two older techniques to determine whether there is any evidence that 3DCRT, a conformal technique, provides better outcomes or fewer or less severe adverse events than 2DRT.

Twelve comparisons of 3DCRT versus 2DRT were reviewed. As Table 17 shows, three comparisons included only nasopharyngeal cancer patients; two nasal cavity/paranasal sinus cancer patients; one comparison each, for oropharyngeal, unknown primary, and laryngeal cancer patients; and four comparisons among patients with a mix of cancer sites. One randomized, controlled trial was included, and two comparisons were from prospective observational studies; the remainder were retrospective.

Table 17 3DCRT vs. 2DRT: Summary of study design, quality, and key outcomes

Site | Studies | n | RCT | Prospective Observational | Assessor Blinded | Groups Comparable | Treatments in same time period | Well-done multivariable analysis/intention- to-treat | USPSTF Good/Fair
NPC | 3 | 370 | 1 | 1 | 0 | 0 | 1 | 0 | 0/0
OPH | 1 | 130 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
PNS | 2 | 231 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
UNP | 1 | 87 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
LAR | 1 | 122 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
MIX | 4 | 557 | 0 | 2 | 0 | 1 | 2 | 0 | 0/0
Total | 12 | 1497 | 1 | 3 | 0 | 1 | 3 | 0 | 0/0

Outcome | Total No. studies | Large (> 15 pctg pts) 3DCRT-2DRT difference | | | | Moderate (6–15 pctg pts) 3DCRT-2DRT difference | | | | Small (0–5 pctg pts) 3DCRT-2DRT difference | | | | Unquantifiable 3DCRT-2DRT difference
Outcome | Total No. studies | No. Studies | Sig | NS | P NR | No. Studies | Sig | NS | p NR | No. Studies | Sig | NS | p NR | No. Studies | Sig | NS | p NR
Acute xerostomia | 1 | | | | | | | | | 1 | | 1?
Late xerostomia | 4 | 2 | 1+ | 1+ | | 2 | | 1+ | 1−
Acute mucositis | 4 | | | | | 1 | | 1+ | | 3 | | 1? | 1+ 1−
Late mucositis | 2 | | | | | | | | | 2 | | 1? | 1+
Acute dysphagia | 1 | | | | | | | | | 1 | | 1?
Late dysphagia | 0
Acute skin toxicity | 3 | | | | | | | | | 3 | | 1? | 2+
Late skin toxicity | 3 | | | | | 1 | | | 1+ | 2 | | | 1+ 1=
Acute osteoradionecrosis/bone toxicity | 0
Late osteoradionecrosis/bone toxicity | 2 | | | | | | | | | 2 | | | 1− 1=
Tumor control | 8 | 2 | 1+ | 1+ | | 2 | | 2+ | | 4 | | 2+ 2?
Patient survival | 7 | 1 | | 1+ | | 2 | | 2+ | | 4 | | 1+ 1− 2?

+: favors IMRT; −: favors 3DCRT; ?: unclear which group is favored; =: same result for both groups

Statistical significance is based on multivariable analyses, where available; if only univariate results are reported, those are used.

All of the studies were rated poor according to the USPSTF criteria. None reported blinded assessors or well-done multivariable analyses. It was unclear whether the randomized, controlled trial used an intention-to-treat approach. The groups were reported to be comparable in only one study. The alternative treatments were provided during different time periods or it was unclear in 9 comparisons. This could bias the results against the older technique, assuming that it continued to evolve over time so that a concurrent comparison might be more favorable.

No consistent between-group differences were found for any outcomes. The adverse event, tumor control, and survival outcomes are summarized in the second part of Table 17; adverse event comparisons that report numerical differences in incidence are presented graphically in Appendix C, Figures C10–C15. Between-group differences for two outcomes were statistically significant: one of four comparisons for the incidence of late xerostomia and one of two comparisons for tumor control. The significant late xerostomia result was in a retrospective study and the magnitude of the difference was more than twice as large as the differences for the other three studies. This comparison and two other nonsignificant comparisons of the proportion of patients with late xerostomia favored 3DCRT; the fourth comparison favored 2DRT. Because of the variation in the magnitude of the between-group differences and the inconsistency in the direction of the results, no conclusions can be drawn regarding the impact of 3DCRT versus 2DRT on late xerostomia incidence.

The second statistically significant, between-group difference was a univariate analysis of local control favoring 3DCRT in the single randomized, controlled trial. However, it was unclear whether the groups were comparable at baseline or whether an intention-to-treat approach was used in the analysis. Four other studies reported on local control, and none of the between-group differences were statistically significant (one univariate analysis, three multivariable analyses). Evidence from multiple, higher quality studies would be needed to determine whether local control is extended for patients receiving treatment with 3DCRT versus 2DRT.

Health-related quality of life using the EORTC QLQ-C30 and H&N-35 (see Table 3, Methods chapter, for a description of these instruments) was reported in one study; no statistical comparisons were reported (see Table 18).

Table 18 3DCRT vs. 2DRT: Summary of quality of life data

Study | EORTC QLQ-C30(# domains) | | | EORTC H&N-35(# domains) | | | SF-36 (# domains) | | | Other (HNCI, HNQOL) (# domains)
Study | + | NS | — | + | NS | — | + | NS | — | + | NS | —
Fang et al. 2007[32] | NR | | | NR

KEY:

+ statistically significant difference in favor of more conformal modality (listed first in comparison in 1^st^ column)

NS difference not statistically significant

— statistically significant difference in favor of less conformal modality (listed second in comparison in 1^st^ column)

* Between-group difference in total score, adjusted for baseline score.

When none of the between-group differences were consistently moderate to large in size and statistically significant for an outcome, no conclusion can be drawn about the relative impact of these two types of radiotherapy. This situation occurred for the following outcomes: acute xerostomia, acute mucositis, late mucositis, acute dysphagia, late skin toxicity, late osteoradionecrosis and bone toxicity, locoregional control, disease-free survival, disease-specific survival, and overall survival.

More detailed information on the 3DCRT-2DRT comparisons is presented in the following sections, grouped by cancer site (nasopharyngeal, oropharyngeal, nasal cavity/paranasal sinuses, unknown primary tumor, laryngeal, and mixed tumor sites) and then treatment setting. Setting refers to the order in which radiotherapy is given relative to surgery and chemotherapy and whether all patients in a given study followed the same sequence. Settings are not differentiated by the specific type of chemotherapy received.

3DCRT Versus 2DRT: Nasopharyngeal Cancer, Primary Radiotherapy. A single study by Jen et al.73 (Table 19) compared 3DCRT and 2DRT in patients receiving primary radiotherapy for nasopharyngeal cancer. A multivariable analysis produced an odds ratio for the key outcome, severe xerostomia, with a value of 0.55 (p=.0053), a reduced risk for 3DCRT relative to 2DRT. The xerostomia odds ratio was adjusted for gender, but it is unclear why other patient covariates were not retained. Time of xerostomia had a significant main effect and there was a significant treatment group by time interaction, showing similar occurrence levels during and immediately after treatment, but increasing between-group differences in later periods. The prescribed dose for all patients was 70 Gy. Groups in this retrospective study were comparable by sex (15 percent female in the 3DCRT group; 18 percent female in the 2DRT group), age (median: 43 and 44 years, respectively), and disease stage (60 percent and 58 percent stage III/IV, respectively). However, the main quality concerns about this study are uncertainty about whether groups were treated in the same time period and use of poor quality multivariable analysis methods. Thus, this study provides weak evidence on the relative frequency of xerostomia for 3DCRT versus 2DRT.

Table 19 3DCRT vs. 2DRT: Summary of studies of nasopharyngeal cancer

Study & Setting(s) | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Jen et al. 2005[73] Primary radiotherapy | Xerostomia | 180 | | Late, severe OR: 0.55, p=.0053 OR adjusted for gender RT technique by time interaction (p=.032), with larger between-group differences in later periods | Retrospective | Unclear | Unclear | No | Poor
Wu et al. 2005[85] RCT Primary radiotherapy plus split chemotherapy | Mucositis | 96 | Acute, Gr 3–4, Δ−6, NS | | Prospective | Unclear | Yes | Unclear if intention-to-treat | Poor
Wu et al. 2005[85] RCT Primary radiotherapy plus split chemotherapy | Local control | 96 | 1 yr., Δ+20, .003 | | | | | Unclear if intention-to-treat
Wu et al. 2005[85] RCT Primary radiotherapy plus split chemotherapy | Overall survival | 96 | 1 yr., Δ+4, NS
Fang et al. 2007[32] Mixed settings: Primary RT ± chemotherapy with unclear timing | Quality of life | 94 | [underlined: 24–36 mos., EORTC QLQ-C30] Group means presented but no statistical test results given for all domains: Global Health, Physical Function, Role Function, Emotional Function, Cognitive Function, Social Function, Fatigue, Nausea/Vomiting, Pain, Dyspnea, Insomnia, Appetite Loss, Constipation, Diarrhea, Financial Difficulties [underlined: EORTC QLQ-H&N35] Group means presented but no statistical test results given for all domains: Pain, Swallowing, Taste/smell, Social eating, Social contract, Sexuality, Teeth, Opening mouth, Dry mouth, Sticky saliva, Coughing, Feeling ill | | Retrospective | Unclear | No | Off-topic | Poor
Fang et al. 2007[32] | Xerostomia | 94 | [underlined: 24–36 mos., EORTC QLQ-H&N35 Dry Mouth item] Group means presented but no statistical test results given

Abbreviations: Δ: change; Gr: grade; mos.: months; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

3DCRT Versus 2DRT: Nasopharyngeal Cancer, Primary Radiotherapy Plus Split Chemotherapy. A single randomized trial by Wu et al.85 (Table 19) compared late-course 3DCRT and all-course 2DRT among patients with nasopharyngeal cancer receiving primary radiotherapy plus split chemotherapy. Each group received a course of platinum-based chemotherapy before and after radiotherapy. It is unclear whether allocation of patients to intervention groups was unbiased. The method involved drawing one of 20 numbers randomly for each patient; odd numbers were assigned to the treatment group and even numbers were assigned to the control group. While groups appeared similar with respect to sex (35 percent female for 3DCRT and 34 percent female for 2DRT), age (median: 45 and 44 years, respectively) and stage (all III/IV), uncertainty about the allocation method clouds whether groups are comparable on a sufficient range of prognostic factors. It is unclear if intention-to-treat analysis was conducted, a key quality metric in assessing randomized, controlled trials. The frequency of acute mucositis was slightly but nonsignificantly higher in the 3DCRT group. Local control was significantly better at one year in the 3DCRT group (.003). Overall survival at one year was similar in the two groups (p=NS). This single poor-quality trial provides very weak evidence on the comparative effects of 3DCRT and 2DCRT on nasopharyngeal cancer in the setting of primary radiotherapy plus split chemotherapy.

3DCRT Versus 2DRT: Nasopharyngeal Cancer, Mixed Settings. The only study addressing 3DCRT versus 2DRT for nasopharyngeal cancer in mixed settings is the three-arm design from 2007 described by Fang et al.32 (Table 19). The proportions of patients who were female were 24 percent and 28 percent for the 3DCRT and 2DRT groups, respectively; media age in both groups was 51 years, and percentages in stage III or IV were 48 percent and 51 percent, respectively. The article provides group mean values for specific domains of two QOL scales: EORTC QLQ-C30 and EORTC QLQ-H&N35. No statistical tests were performed comparing 3DCRT and 2DRT. These authors compared two mixed groups: one consisting of a combination of those receiving 2DRT or 2DRT but 3DCRT boost and a second receiving either 3DCRT or IMRT. This mixing of patient groups does not address the questions of concern to this review.

3DCRT Versus 2DRT. Oropharyngeal Cancer, Mixed Settings. There was only one comparison of 3DCRT and 2DRT among patients with oropharyngeal cancer. The Rades et al.81 three-arm study with mixed settings compared 3DCRT versus 2DRT in oropharyngeal cancer (Table 20). Outcomes were either comparable or nonsignificantly in favor of 3DCRT in this study. Age and gender distributions were not reported; cancer stage was III or IV in 65 percent or more in the 3DCRT group and 54 percent or more in the 2DRT group; and the prescribed primary tumor dose was 60–70 Gy in both groups.

Table 20 3DCRT vs. 2DRT: Summary data for oropharyngeal cancer

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Rades et al. 2007[81] | Postoperative RT ± concurrent chemotherapy | Xerostomia | 130 | Late, Gr 2–3, Δ+10, p NR | | Retrospective | Yes | Yes, WL | Not done | Poor
Rades et al. 2007[81] | | Mucositis | | Acute, Gr 2–3, Δ+3, p NR | | | | | Not done
Rades et al. 2007[81] | | Skin toxicity | | Acute, Gr 2–3, Δ−3, p NR Late, Gr 2–3, Δ−2, p NR | | | | | Not done
Rades et al. 2007[81] | | Local control | | 2 yr. Δ+1, NS | NS | | | | Unclear
Rades et al. 2007[81] | | Overall survival | | 2 yr. Δ+8, NS | NS | | | | Unclear

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

No statistically significant differences in outcomes were reported for the single comparison of 3DRT and 2DRT: For adverse events (e.g., late xerostomia, acute mucositis, acute and late skin toxicities), no statistical tests were reported. For local control and overall survival, neither the univariate nor multivariable analyses produced statistically significant results.

This study provided insufficient evidence to draw any conclusions on the comparative effectiveness of 3DCRT and 2DRT among patients with oropharyngeal cancer.

3DCRT Versus 2DRT. Nasal Cavity and Paranasal Sinuses, Mixed Settings. There were two comparative studies67,68 that included only patients with cancer of the nasal cavity and/or paranasal sinuses; neither was a randomized, controlled trial (Table 21). Both provide data comparing 3DCRT to 2DRT. The study by Chen et al.67 had three arms, two of which compared 3DCRT to 2DRT; while the Dirix et al.68 study had a 3DCRT arm and a 2DRT arm. Both studies have a mix of settings, with variations in the timing of radiotherapy within each study; Chen et al.67 also includes chemotherapy for 15 percent of patients, some concurrent and some postradiotherapy. Chen et al.67 reported no multivariable analysis, while Dirix et al. 68 described one that is flawed. No statistically significant between-group differences were reported.

Table 21 3DCRT vs. 2DRT: Cancer of the nasal cavity/paranasal sinuses, mixed settings

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Dirix et al. 2007[68] | Primary/preoperative/postoperative RT | Xerostomia | 127 | Permanent, Δ−20, .08 | | Retrospective | Unclear | No | Not done | Poor
Dirix et al. 2007[68] | | Mucositis | 127 | Late, Δ?, NS | | | | | Not done
Chen et al. 2007[67] | Primary/preoperative/postoperative RT ± post-RT/concurrent chemotherapy | Mucositis | 104 | Late, ≥ Gr 3, Δ−1, p NR | | Retrospective | Unclear | No | Not done | Poor
Chen et al. 2007[67] | | Skin toxicity | 104 | Late, ≥ Gr 3, Δ−8, p NR | | | | | Not done
Dirix et al. 2007[68] | | Osteoradionecrosis/bone toxicity | 127 | Late, ungraded, Δ=0, p NR | | | | | Not done
Chen et al. 2007[67] | | Osteoradionecrosis/bone toxicity | 104 | Late, ≥ Gr 3, Δ+1, p NR | | | | | Not done
Dirix et al. 2007[68] | | Local control | 127 | NS | | | | | No
Chen et al. 2007[67] | | Local control | 104 | 5 yr., Δ+3, NS | | | | | Not done
Dirix et al. 2007[68] | | Disease-free survival | 127 | NS | | | | | No
Chen et al. 2007[67] | | Disease-free survival | 104 | NS | | | | | Not done
Dirix et al. 2007[68] | | Disease-specific survival | 127 | NS | | | | | No
Dirix et al. 2007[68] | | Overall survival | 127 | NS | | | | | No
Chen et al. 2007[67] | | Overall survival | 104 | 5 yr., Δ+6, NS | | | | | Not done

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

The Dirix et al.68 two-arm study had 127 subjects: 16 percent were women, the median age was 58, and more than 90 percent had stage III or stage IV cancer. The timing of radiotherapy was mixed; no chemotherapy was used. The primary tumor prescribed dose was 50–80 Gy. Fewer patients in the 3DCRT group had permanent xerostomia (p=.08, NS); the frequency of late mucositis was similar in both groups (p not reported). No late osteoradionecrosis was reported in either group. No statistically significant differences (magnitudes not reported) in local control, disease-specific survival, disease-free survival, or overall survival were found in this study.

The study population for the Chen three-arm study67 is described above; 104 subjects were in the 3DCRT and 2DRT groups. The primary tumor prescribed dose was 50–74 Gy (versus 50–73 Gy for 3DCRT). The frequency of both late mucositis and osteoradionecrosis or bone toxicity was similar in the 3DCRT and 2DRT groups; late skin toxicity was slightly less common in the 3DCRT group. No statistical tests were reported for these three comparisons. The five-year local control rate was similar for 3DCRT and 2DRT, while overall survival was slightly higher with 3DCRT. Neither of these comparisons was statistically significant, nor was the comparison in disease-free survival between treatment groups.

These studies provided insufficient evidence to draw any conclusions on the comparative effectiveness of 3DCRT and 2DRT among patients with nasal cavity/paranasal sinus cancer.

3DCRT Versus 2DRT: Unknown Primary Cancers, Mixed Settings. A single study compared 3DCRT to 2DRT among patients with unknown primary tumors (Beldi et al.63). The retrospective study has a mix of treatment settings, and all 87 subjects have III or IV cancer (Table 22). Radiotherapy was primary or postoperative; some patients received chemotherapy before or with radiotherapy. The typical subject in this study was male (18 percent female) around 60 years of age (median: 59 years) and with advanced cancer. The primary tumor prescribed dose was 45–70 Gy. Two outcomes were reported: disease-free and overall survival at five years. For both, outcomes were significantly better for 3DCRT than for 2DRT group in a univariate analysis (p<.01), but the difference was not statistically significant in the multivariable analysis, which was flawed by use of arbitrary significance levels for inclusion in the model. Adverse events were not reported.

Table 22 3DCRT vs. 2DRT: Summary data on mixed settings for unknown primary cancers

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Beldi et al. 2007[63] | Primary/postoperative RT ± pre-RT/concurrent chemotherapy | Disease-free survival | 87 | 5 yr., Δ+33, <.01 | NS | Retrospective | Unclear | No | No | Poor
| | Overall survival | 87 | 5 yr., Δ+43, <.01 | NS

This study provided insufficient evidence to draw any conclusions on the comparative effectiveness of 3DCRT and 2DRT among patients with unknown primary cancer.

3DCRT Versus 2DRT: Laryngeal Cancers, Primary Radiotherapy. A single study compared 3DCRT with 2DRT in 122 patients with laryngeal cancer patients only (Zouhair et al.;87 see Table 23). All patients were treated in a single setting, with primary radiotherapy. The typical study subject was male (percent female=13 percent), was late middle aged (median=62 years), and did not have advanced cancer (no stage III or IV). The prescribed dose to the primary tumor ranged from 60 to 74 Gy. No adverse event outcomes were reported. The single effectiveness outcome was local control: There was no statistically significant difference between 3DCRT and 2DRT at 5 years in univariate (86 percent versus 81 percent, p=.55) or multivariable analyses.

Table 23 3DCRT vs. 2DRT: Summary data on single setting for laryngeal cancers

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Zouhair et al. 2004[87] | Primary RT | Local control | 122 | 5 yr., Δ+5, NS | NS | Retrospective | No | No | Unclear | Poor

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

This study provided insufficient evidence to draw any conclusions on the comparative effectiveness of 3DCRT and 2DRT among patients with laryngeal cancer.

3DCRT Versus 2DRT: Mixed Tumor Sites, Mixed Settings. Studies including patients with a variety of tumor sites are difficult to interpret, because the impact of radiotherapy modalities on outcomes may vary by tumor site, e.g., if the tumor is adjacent to a particular critical structure. Four studies70,74,80,82 with mixed tumor sites compared outcomes of 3DCRT and 2DRT, and all had mixed settings (Table 24). None of the treatment group differences in outcomes was statistically significant.

Table 24 3DCRT vs. 2DRT: Summary data on mixed settings for mixed tumor sites

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Rades et al. 2008[82] | Primary/postoperative RT± concurrent chemotherapy | Xerostomia | 345 | Late, Gr 2–3, Δ−15, .06 | | Retrospective | Yes | Unclear | No | Poor
Palazzi et al. 2008[80] | Primary/postoperative RT ± concurrent ± pre-RT chemotherapy | Xerostomia | 116 | Acute | NS | Prospective | Unclear | No | Unclear | Poor
Kuhnt et al. 2005[74] | Primary/postoperative RT | Salivary flow | 33 | 10 wks., salivary flow rate +, <0.1 | | Prospective | Unclear | Yes | Not done | Poor
Palazzi et al. 2008[80] | | Dysphagia | 116 | Acute, > Gr 2 | NS
Rades et al. 2008[82] | | Mucositis | 345 | Acute, Gr 2–3, Δ−5, p NR
Palazzi et al. 2008[80] | | Mucositis | 116 | Acute, > Gr 2 | NS
Rades et al. 2008[82] | | Skin toxicity | 345 | Acute, Gr 2–3, Δ−4, p NR Late, Gr 2–3, Δ0, p NR
Palazzi et al. 2008[80] | | Skin toxicity | 116 | Acute, > Gr 2 | NS
Rades et al. 2008[82] | | Locogregional control | 345 | 3 yr., Δ+3, NS
Gomez et al. 2008[70] | Primary/postoperative RT ± chemotherapy with unclear timing | Disease-free survival | 32 | NS | Not entered | Retrospective | Unclear | Yes | Unclear | Poor
Rades et al. 2008[82] | | Overall survival | 345 | 3 yr., Δ−5, NS
Gomez et al. 2008[70] | | Overall survival | 32 | NS | Not entered

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; wks: weeks; yr: year;

Two of the comparisons came from two arms of a three-arm study (Gomez et al.,70 Palazzi et al.80); the other two comparisons were from two-arm studies. Patients were treated with primary or postoperative radiotherapy, with or without chemotherapy. Of a total of 526 subjects, the majority were male in three of the studies;74,80,82 the median age was 52–60 (one study82 did not report age); and the percentage of patients with advanced cancer (stage III or IV) ranged from 47.4 percent or more70 to 100 percent,82 with one study 74 not reporting. The prescribed dose to the primary tumor ranged from a minimum of 52 Gy to a maximum of 72 Gy in three studies;70,80,82 the dose in the fourth74 was unclear.

None of these studies reported on QOL, and none of the treatment group difference in adverse effects was statistically significant. The adverse outcomes measured were acute xerostomia,80 late xerostomia,82 salivary flow at 10 weeks, 74 acute dysphagia, 80 acute mucositis 80 (p not reported in one study82), acute skin toxicity80 (p not reported in one study 82), and late skin toxicity82 (p not reported). One tumor control outcome was reported —three-year locoregional control—and the treatment group difference was not statistically significant.82 Differences in two patient survival outcomes were reported—disease-free survival70 and overall survival (at three years for one study,82 time not reported for another 70)—and none was statistically significant.

These studies provided insufficient evidence to draw any conclusions on the comparative effectiveness of 3DCRT and 2DRT among patients with mixed tumor sites, which are also inherently difficult to generalize.

### Comparative Studies, IMRT Versus 2DRT

#### Overview

This section compares 2DRT, which is the oldest radiotherapy technique included in this review, to IMRT, which is the newest and is also conformal, to determine whether there is any evidence that IMRT provides better outcomes or fewer or less severe adverse events than 2DRT.

Twenty-two comparisons of IMRT versus 2DRT were reviewed. As Table 25 shows, 6 comparisons included only nasopharyngeal cancer patients; 4, oropharyngeal cancer patients; 1 comparison each, for nasal cavity/paranasal sinus and unknown primary cancer patients; and 10 comparisons, patients with a mix of cancer sites. There were no comparisons of IMRT versus 2DRT among laryngeal cancer patients alone. Two randomized, controlled trials were included, and five comparisons were from prospective observational studies; the remainder were retrospective.

Table 25 IMRT vs. 2DRT: Summary of study design, quality, and key outcomes

Site | Studies | n | RCT | Prospective Observational | Assessor Blind | Groups Comparable | Treatments in same time period | Well-done multivariable analysis/intention-to-treat | USPSTF Good/Fair
NPC | 6 | 662 | 2 | 3 | 1 | 3 | 3 | 1 | 0/1
OPH | 4 | 717 | 0 | 1 | 0 | 0 | 0 | 0 | 0/0
PNS | 1 | 82 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
UNP | 1 | 41 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
LAR | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0/0
MIX | 10 | 939 | 0 | 3 | 0 | 0 | 2 | 0 | 0/0
Total | 22 | 2441 | 2 | 7 | 1 | 3 | 5 | 1 | 0/1

Outcome | Total No. studies | Large (>15 pctg pts) IMRT-2DRT difference | | | | Slight-moderate (6–15 pctg pts) IMRT-2DRT difference | | | | Negligible (0–5 pctg pts) IMRT-2DRT difference | | | | Unquantifiable IMRT-2DRT difference
Outcome | Total No. studies | No. Studies | Sig | NS | p NR | No. Studies | Sig | NS | p NR | No. Studies | Sig | NS | p NR | No. Studies | Sig | NS | p NR
Acute xerostomia | 5 | 2 | 2+ | | | | | | | 3 | | 2+ 1?
Late xerostomia | 9 | 5 | 5+ | | | | | | | | | | | 4 | 3+ | 1+
Acute mucositis | 6 | 1 | 1+ | | | 3 | | 2+ | 1− | 2 | | 1? | 1+
Late mucositis | 3 | 1 | | | 1+ | | | | | 2 | | | 2+
Acute dysphagia | 5 | 4 | 3+ | 1+ | | | | | | 1 | | 1?
Late dysphagia | 2 | 1 | 1+ | | | | | | | 1 | | | 1=
Acute skin toxicity | 6 | 3 | | 2+ | 1+ | | | | | 3 | | 1? | 1+ 1−
Late skin toxicity | 5 | 2 | 2+ | | | 3 | | | 3+
Acute osteoradionecrosis/bone toxicity | 0
Late osteoradionecrosis/bone toxicity | 3 | | | | | 2 | | | 2+ | 1 | | | 1+
Tumor control | 6 | 1 | | 1+ | | 4 | | 4+ | | 1 | | | 1?
Patient survival | 7 | 2 | 1+ | 1+ | | 3 | | 3+ | | 2 | | 1− 1?

+: favors IMRT; −: favors 3DCRT; ?: unclear which group is favored; =: same result for both groups

All of the studies were rated poor according to the USPSTF criteria, except for one randomized, controlled trial on nasopharyngeal patients that was rated fair. 41 Only the latter reported using blinded assessors, had a well-done multivariable analysis, and the groups were comparable at baseline. It was rated fair because the treatment settings were mixed, making it difficult to separate the impact of IMRT or 2DRT from differences in timing of radiotherapy and the use of additional therapies. Furthermore, an unspecified number of patients also received brachytherapy. The second randomized, controlled trial was rated poor because it was unclear whether it used an intention-to-treat approach. In 18 of the comparisons, the alternative treatments were provided during different time periods or it was unclear. This could bias the results against the older technique, assuming that it continued to evolve over time so that a concurrent comparison might be more favorable.

Adverse events, tumor control, and survival outcomes are summarized in the second part of Table 25; adverse event comparisons that report numerical differences in incidence are presented graphically in Appendix C, Figures C16–C24. Consistent between-group differences were found for two outcomes: late xerostomia and health-related quality of life domains related to xerostomia. Nine studies reported on late xerostomia, and eight were statistically significant in favor of IMRT. Among the studies that reported frequency, the range of differences between IMRT and 2DRT was 43 to 62 percentage points (Figure C17 in Appendix C).

Health-related quality of life using the EORTC QLQ-C30 and H&N-35 (see Table 3, Methods chapter, for a description of these instruments) was reported in three studies; Pow et al.28 reported statistically significant between-group comparisons favoring IMRT for 11 of 41 domains across three instruments; while Yao et al. 36 reported 1 of 4 statistically significant differences; the between-group differences in total scores in Jabbari et al. 30 was not statistically significant (see Table 26). Where domains addressed specific adverse events, such as reports on dry mouth and xerostomia, the results were combined with other measures discussed above. Overall, there is a low level of evidence from these studies that quality of life is greater in patients treated with IMRT compared to 2DRT.

Table 26 IMRT vs. 2DRT: Summary of quality of life data

Study | EORTC QLQ-C30 (# domains) | | | EORTC H&N-35 (# domains) | | | SF-36 (# domains) | | | Other (HNCI, HNQOL) (# domains)
Study | + | NS | — | + | NS | — | + | NS | — | + | NS | —
Pow et al. 2006[28] | 2 | 14 | | 7 | 11 | | 2 | 5
Yao et al. 2007[36] | | | | | | | | | | 1 | 3
Jabbari et al. 2005[30] | | | | | | | | | | | 1^*^

KEY:

+ statistically significant difference in favor of more conformal modality (listed first in comparison in 1^st^ column)

NS difference not statistically significant

— statistically significant difference in favor of less conformal modality (listed second in comparison in 1^st^ column)

* Between-group difference in total score, adjusted for baseline score.

Additional between-group differences that had some statistically significant results are as follows: Two of five comparisons for the incidence of acute xerostomia, one of six comparisons for acute mucositis, two of five comparisons of acute dysphagia, one of two comparisons of late dysphagia, two of five comparisons for late skin toxicity, and none of seven for disease-free survival. Because of the variation in the proportion of studies with statistically significant between-group differences for each adverse event or outcome and the quality or limitations of the specific studies involved, conclusions can be drawn only regarding the impact of IMRT versus 2DRT on late xerostomia incidence and quality of lifedomains related to xerostomia. No between-group differences were statistically significant for the following outcomes: late mucositis, acute skin toxicity, late osteoradionecrosis and bone toxicity, and locoregional control.

More detailed information on the IMRT-2DRT comparisons is presented in the following sections, grouped by cancer site (nasopharyngeal, oropharyngeal, nasal cavity/paranasal sinuses, unknown primary tumor, and mixed tumor sites) and then treatment setting. Setting refers to the order in which radiotherapy is given relative to surgery and chemotherapy and whether all patients in a given study followed the same sequence. Settings are not differentiated by the specific type of chemotherapy received.

IMRT Versus 2DRT: Nasopharyngeal Cancer, Primary Radiotherapy. Of the two studies comparing IMRT and 2DRT among patients receiving primary radiotherapy for nasopharyngeal cancer (Table 27), the randomized trial by Pow et al.28 provides suggestive evidence on quality of life, xerostomia, and salivary flow. Pow et al.28 conducted a randomized trial in patients with stage I or II disease and excluded patients with local and/or distant failures. This trial did not analyze results using an intent-to-treat approach, thus it received a poor USPSTF rating. These authors administered three quality of life scales at 2, 6, and 12 months: SF-36, EORTC QLQ-C30, and EORTC QLQ-H&N35 (see Table 3 in the Methods chapter for descriptions of these instruments). Statistical tests were performed both at the individual followup points and for the entire series of points. Key statistically significant findings favoring IMRT for the entire followup series included these domains on the EORTC QLQ-H&N35: Dry Mouth, Sticky Saliva, Swallowing and Speech Problems. Other findings include statistically significant advantages for IMRT at 12 months for two SF-36 domains, Role-Physical and Bodily Pain. While these authors did not specifically quantify the clinical significance of their results, a small trial (n=45) that achieves statistical significance generally means the effect sizes are moderate to large.

Table 27 IMRT vs. 2DRT: Summary of studies of nasopharyngeal cancer

Study | Setting | Outcome | n | Univariate p value | Multivariable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Pow et al. 2006[28], RCT | Primary RT | Quality of life | 45 | 2/6/12 mos. [underlined: SF-36] Role-Physical, 12 mo IMRT+ <.05, all other F/U NS Bodily pain, 12 mo IMRT+ <.05, all other F/U NS All other domains, all F/U NS: Physical Function, Vitality, Social Functioning, Role-Emotional, Mental Health [underlined: EORTC QLQ-C30] Role Function-Revised, 12 mos. IMRT+ <.05, all other F/U NS Diarrhea, 2 mos. IMRT-<.05, series IMRT- .009, other F/U NS All other domains, all F/U NS: Global Health, Global Health-Revised, Physical Function, Role Function, Emotional Function, Cognitive Function, Social Function, Fatigue, Nausea/Vomiting, Pain, Dyspnea, Insomnia, Appetite Loss, Constipation, Financial Difficulties [underlined: EORTC QLQ-H&N35] Swallowing, 12 mos. IMRT+ <.05, series IMRT+ .022, other F/U NS Taste/Smell, 2 mos. IMRT+ <.05, all other F/U NS Speech, 6 mos. IMRT+ <.05, 12 mos. IMRT+ <.05, series IMRT+ .053, 2 mos. NS Dry Mouth, series IMRT-.021, all other F/U NS Sticky Saliva, 2/6/12 mos. IMRT-<.05, series IMRT-<.001 Coughing, 6 mos. IMRT-<.05, all other F/U NS Weight Gain, 2 mos. IMRT-<.05, all other F/U NS All other domains, all F/U NS: Pain, Social Eating, Social Contact, Sexuality, Teeth, Opening Mouth, Feeling Ill, Pain Killers, Nutrition Supplement, Feeding Tube, Weight Loss | | Prospective | Yes | Yes | No ITT | Poor
Wu et al. 2005[86] Primary radiotherapy | | Xerostomia | 380 | Acute, Gr ?, Δ-3, p NR | | Retrospective | Unclear | Unclear | Not done | Poor
Pow et al. 2006[28], RCT | | Salivary flow | 45 | 2/6/12 mo stimulated whole saliva flow ANOVA IMRT+ <.003 Stimulated parotid saliva flow ANOVA IMRT+ <.002 | | Prospective | Yes | Yes | No ITT | Poor
Wu et al. 2005[86] | | Salivary flow | 380 | ? mo, static secretion function, IMRT+ <.05
Laskar et al. 2008[75] | Primary RT + split chemotherapy | Xerostomia | 36 | Acute, ≥ Gr 2, Δ-56, .002 | | Prospective | Yes | Yes | Not done | Poor
| | Dysphagia | 36 | Acute, ≥ Gr 2, Δ-52, .01 Acute, ≥ Gr 3, Δ-30, .035 | | | | | Not done
| | Mucositis | 36 | Acute, ≥ Gr 2, Δ-20, .066 Acute, ≥ Gr 3, Δ-37, .033 | | | | | Not done
| | Skin toxicity | 36 | Acute, ≥ Gr 2, Δ-16, NS Acute, ≥ Gr 3, Δ-42, .006 | | | | | Not done
| | Locoregional control | 36 | 2 yr. Δ +16, NS | Not entered | | | | Unclear
| | Disease-free survival | 36 | 2 yr. Δ +12, NS | Not entered | | | | Unclear
| | Overall survival | 36 | 2 yr. Δ +14, NS | Not entered | | | | Unclear
Fang et al. 2007[32] | Primary RT ± chemotherapy with unclear timing | Quality of life | 94 | [underlined: 24–36 mos., EORTC QLQ-C30] Group means presented but no statistical test results given for all domains: Global Health, Physical Function, Role Function, Emotional Function, Cognitive Function, Social Function, Fatigue, Nausea/Vomiting, Pain, Dyspnea, Insomnia, Appetite Loss, Constipation, Diarrhea, Financial Difficulties [underlined: EORTC QLQ-H&N35] Group means presented but no statistical test results given for all domains: Pain, Swallowing, Taste/smell, Social eating, Social contract, Sexuality, Teeth, Opening mouth, Dry mouth, Sticky saliva, Coughing, Feeling ill | | Retrospective | Unclear | No | Off-topic | Poor
Fang et al. 2007[32] | | Xerostomia | 94 | [underlined: 24–36 mos., EORTC QLQ-H&N35 Dry Mouth item] Group means presented but no statistical test results given
Kam et al. 2007[41] (RCT) | Primary RT ± intracavitary brachytherapy | Xerostomia | 56 | Acute, Gr 2–4, Δ-40, .002 Late, Gr 2–4, Δ-43, .001 1.5/6/12 mos., change in total from 6-item Xerostomia Scale, all F/U NS | | Prospective | Yes | Yes | Yes ITT | Fair
Hsiung et al. 2006[72] | Primary RT± concurrent chemotherapy | Xerostomia | 32 | Late, Gr 2–4, Δ-50 <.001 | | Retrospective | No | No | Not done | Poor
Kam et al. 2007[41] (RCT) | | Salivary flow | 56 | 1.5/6/12 mos., stimulated whole saliva flow rate 12 mo IMRT+ <.01 Stimulated parotid saliva flow rate 1.5/6/12 mos. IMRT+ <.001

Abbreviations: Δ: change; Gr: grade; mos.: months; NR: not reported; NS: not significant; RT: radiotherapy; wks: weeks; yr: year;

A second study, by Wu et al.86 was a retrospective design that did not show whether groups were comparable or were treated in the same time period and did not conduct a multivariable analysis. This nonrandomized study reported similar proportions of patients with acute xerostomia, but no statistical test results were provided. Wu et al. included a combined group of patients that was 32 percent female, had a median age of 38 years, and were mostly stage III/IV (86 percent).The prescribed dose was 75 Gy in the IMRT group and 70 Gy in the 2DRT group. The randomized trial and the nonrandomized study both reported significant advantages for IMRT with respect to salivary flow in the acute phase and in the late phase in the randomized trial.

IMRT Versus 2DRT: Pediatric Nasopharyngeal Cancer, Primary Radiotherapy Plus Split Chemotherapy. Laskar et al.75 (Table 27) conducted a prospective, nonrandomized comparison of IMRT and 2DRT in 36 children with nasopharyngeal cancer. Allocation to treatment was based on physician preference and logistic factors. Multivariable analysis was conducted for tumor control outcomes and overall survival but details are lacking to confirm whether these analyses were well done. The overall USPSTF quality rating was poor. Groups were somewhat comparable. The percentages for IMRT and 2DRT recipients for these variables were: female participants, 26 percent and 18 percent; age over 14 years, 37 percent and 47 percent; larger tumors, 32 percent and 59 percent; and stage III/IV, 84 percent and 94 percent. All patients were given a prescribed dose of 70 Gy. Two cycles of platinum-based chemotherapy was given before radiotherapy and two cycles afterwards. Significantly lower proportions of IMRT patients experienced acute xerostomia, dysphagia, mucositis, and skin problems. However, multivariable analysis was not done for any of these adverse events, despite imbalances between groups. Tumor control (locoregional control and disease-free survival) was nonsignificantly higher at two years in the IMRT group; the same was observed for overall survival. Multivariable analyses were conducted for these three outcomes, but details were unclear. Radiotherapy technique was not entered into any of these analyses. Multivariable analysis for such small data sets is vulnerable to over fitting. A limitation in interpreting these results is that the baseline differences between groups on tumor size and stage somewhat favored the IMRT arm.

IMRT Versus 2DRT: Nasopharyngeal Cancer, Mixed Settings. Due to the clinical diversity of patient groups and treatment modalities, no clear conclusions can be reached from the three studies in Table 27 about the comparative effects of IMRT and 2DRT on quality of life and xerostomia. The randomized trial was reported by Kam et al.41 in 2007, enrolling patients with stage I or II nasopharyngeal cancer. IMRT and 2DRT groups were mostly similar, by median age (46 and 51 years), and percentage female (25 percent and 32 percent). Intracavitary brachytherapy (ICBT) was given to some patients in each group, but the proportion receiving ICBT was not reported. Intention-to-treat analysis was performed and the overall USPSTF rating is fair. Physician-rated RTOG/EORTC xerostomia in grades 2 through 4 was significantly less frequent among IMRT in the acute period (6 weeks) and the late period (12 months). The absolute risk difference was 43 percentage points lower in the IMRT group with a 95 percent confidence interval between 20 and 66 percentage points. The University of Michigan Xerostomia Questionnaire (XQ; see Table 3 in the Methods chapter for further details on the instrument) was administered at 6 weeks, 6 months, and 12 months. No significant between-group differences in change in total XQ scores were observed at any followup. Stimulated whole and parotid salivary flow rates were significantly better in the IMRT group at all followup points. Despite the salivary flow findings, the mixed results on xerostomia symptoms and the mixing of treatment modalities (use of ICBT) make these data difficult to interpret.

The 2007 Fang et al.32 study presented mean quality of life data for IMRT and 2DRT, but again did not report statistical test results comparing these groups. The only other study comparing IMRT and 2DRT among patients treated with mixed settings for nasopharyngeal cancer was published by Hsiung et al.72 in 2006. This retrospective study of 32 participants was imbalanced with respect to the percentage receiving concurrent chemotherapy (50 percent versus 75 percent) and proportion with stage III or IV disease (50 percent versus 38 percent), but the percentage of females was similar (31 percent and 25 percent) and the proportion older than age 50 was identical (31 percent). Late xerostomia was less frequent in the IMRT group. No multivariable analysis with adjustment of confounders was conducted. The group receiving 2DRT was a historical series and the USPSTF rating was poor.

IMRT Versus 2DRT: Oropharyngeal Cancer, Primary Radiotherapy Plus Concurrent Chemotherapy. Lee et al.76 compared IMRT to 2DRT among 112 patients with oropharyngeal cancer (Table 28).No statistically significant differences between groups were detected for the tumor control or patient survival outcomes. The IMRT group may have had fewer adverse events, although no multivariable analyses were reported that could control for any baseline between-group differences. As with the previous study, the quality was poor, due to the retrospective design, missing information about group comparability at baseline, and lack of blinded outcome assessors.

Table 28 IMRT vs. 2DRT: Summary data on primary radiotherapy plus concurrent chemotherapy for oropharyngeal cancer

Study | Setting | Outcome | n | Univariate p value | Multi-variable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Lee et al. 2006[76] | Primary RT + concurrent chemotherapy | Xerostomia | 11 2 | Late, ≥ Gr 2, Δ-55, .002 | | Retrospective | Unclear | Unclear | Not done | Poor
Lee et al. 2006[76] | | Mucositis | | Acute, Δ-6, p NR | | | | | Not done
Lee et al. 2006[76] | | Skin toxicity | | Acute, Δ-4, p NR | | | | | Not done
Lee et al. 2006[76] | | Local control | | 5 yr., Δ+10, NS | | | | | Not done
Lee et al. 2006[76] | | Locogregional control | | 5 yr., Δ+17, NS | | | | | Not done
Lee et al. 2006[76] | | Disease-free survival | | 5 yr., Δ+12, NS | | | | | Not done
Lee et al. 2006[76] | | Overall survival | | 5 yr., Δ+19, NS | | | | | Not done
Yao et al. 2007[36] | Primary RT ± chemotherapy with unclear timing | Quality of life | 53 | 12 mos., HNCI-Eating, IMRT+, .007; Speech, IMRT+, .059; Aesthetics, IMRT+, .069; Social Disruption, IMRT+ NS | | Prospective | No | No | Not done | Poor
Rades et al. 2007[81] | Postoperative RT ± concurrent chemotherapy | Xerostomia | 122 | Late, Gr 2–3, Δ-46, .037 | | Retrospective | Yes | Yes, WL | Not done | Poor
Chao et al. 2001[66] | Primary/preoperative/postoperative RT ± concurrent chemotherapy | Xerostomia | 430 | Acute, Gr > 2, def/postop, Δ+6/Δ+1 p NR Late, Gr > 2, def/postop, Δ-54/Δ-62, .0001 | | Retrospective | No | No | Not done | Poor
Chao et al. 2001[66] | | Dysphagia | 430 | Acute, Gr 2–3, def/postop, Δ-16/Δ-22, p NR | | | | | Not done
Rades et al. 2007[81] | | Mucositis | 122 | Acute, Gr 2-3, Δ-4, p NR | | | | | Not done
Chao et al. 2001[66] | | Mucositis | 430 | Acute, Gr 2-3, def/postop, Δ+8/Δ+13, p NR Late, Gr 2–3, def/postop, Δ-2/Δ-17, p NR | | | | | Not done
Rades et al. 2007[81] | | Skin toxicity | 122 | Acute, Gr 2–3, Δ+2, p NR Late, Δ-7, p NR | | | | | Not done
Chao et al. 2001[66] | | Skin toxicity | 430 | Acute, Gr 2-3, def/postop Δ-15/Δ-1, p NR Late, Gr 2–3, def/postop Δ-7/Δ-8, p NR | | | | | Not done
Chao et al. 2001[66] | | Osteoradionecrosis/bone toxicity | 430 | Late, def/postop Δ-6/Δ-3, p NR | | | | | Not done
Rades et al. 2007[81] | | Local control | 122 | 2 yr., Δ+11, NS | | | | | Unclear
Chao et al. 2001[66] | | Locoregional control | 430 | 2 yr., def/postop, Δ+20/Δ+24, NS | | | | | Not done
Chao et al. 2001[66] | | Disease-free survival | 430 | 2 yr., def, Δ+22, .002; postop, Δ+18, .008 | | | | | Not done
Rades et al. 2007[81] | | Overall survival | 122 | 2 yr., Δ+12, NS | | | | | Unclear
Chao et al. 2001[66] | | Overall survival | 430 | 2 yr., def, Δ+43, .001; postop, Δ+29, .003 | | | | | Not done

Abbreviations: Δ: change; Gr: grade; mos.: months; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

Less than 20 percent of the subjects were female, more than 95 percent had stage III or IV cancer, and the prescribed dose to the primary tumor was 66–70 Gy (IMRT) or 70–72 Gy (2DRT).The median age by group was 55 and 56 years. There was a significantly lower incidence of late xerostomia among the IMRT patients (12 percent) compared to those receiving 2DRT (67 percent; p=.002).Slightly fewer patients in the IMRT group had acute mucositis and acute skin toxicity (6 and 4 percentage point differences, respectively), but no statistical tests were reported. At five years, there was no statistically significant difference between the IMRT group and the 2DRT group on the three tumor control outcomes (local control, locoregional control, disease-free survival), and overall patient survival.

IMRT Versus 2DRT: Oropharyngeal Cancer, Mixed Settings. Three studies comparing IMRT and 2DRT in oropharyngeal cancer were clinically diverse studies in terms of whether and when surgery was given and the timing of and/or use of chemotherapy (Table 28).Chao et al. 66 provided separate comparisons between IMRT and 2DRT within definitive and postoperative settings. The 3 -arm Rades et al.81 study and the study by Yao et al. 36 were also in this group. The studies yielded few consistent, statistically significant differences in outcomes between treatment groups.

Late xerostomia appeared less common among patients treated with IMRT than for those treated with 2DRT in both studies66,81 measuring this outcome; no p value was reported for acute xerostomia.66 There was also a statistically significant improvement in the eating domain on a disease-specific quality of life instrument for IMRT versus 2DRT. Results were either statistically nonsignificant or statistical results were not reported for the remaining adverse effects measured (acute dysphagia,66 acute or late mucositis81 [acute only66], acute and late skin toxicity,66,81 and late osteoradionecrosis or bone toxicity 66).

The IMRT group appeared to have better overall survival than the 2DRT group, but the results were statistically significant in one study66 (definitive radiotherapy, p= .001; postoperative radiotherapy, p=.003) and not in the other.81 The difference was statistically significant for higher disease-free survival among both definitive (p=.002) and postoperative (p=.008) IMRT patients in one study.66 There was no statistically significant difference for local control, 81 the one other outcome reported.

One study on oropharyngeal cancer measured quality of life. Yao et al.36 used the Head and Neck Cancer Inventory (HNCI), an instrument whose reliability and validity has been assessed (see Table 3, Methods). In looking at four domains (eating, speech, aesthetics, and social disruption), there was statistically significant improvement in eating over time for IMRT compared to 2DRT (measured at 3, 6, and 12 months, p=.007). The authors characterized the change as of small or medium clinical significance. No other statistically significant differences were reported.

IMRT Versus 2DRT: Nasal Cavity and Paranasal Sinuses, Mixed Settings. There was one comparative study comparing IMRT versus 2DRT among only patients with cancer of the nasal cavity and/or paranasal sinuses, the three-arm study by Chen et al.67 (Table 29).The study has a mix of settings, with variations in the timing of radiotherapy and chemotherapy for 15 percent of patients, some concurrent and some postradiotherapy. The study population, described above in the section comparing IMRT and 3DCRT, included 82 subjects in the IMRT and 2DRT groups.

Table 29 IMRT vs. 2DRT: Cancer of the nasal cavity/paranasal sinuses, mixed settings

Study | Setting | Outcome | n | Univariate p value | Multi-variable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Chen et al. 2007[67] | Primary/preoperative/postoperative RT ± post-RT/concurrent chemotherapy | Mucositis | 82 | Late, ≥ Gr 3, Δ-4, p NR | | Retrospective | Unclear | No | Not done | Poor
Chen et al. 2007[67] | | Skin toxicity | 82 | Late, ≥ Gr 3, Δ-14, p NR | | | | | Not done
Chen et al. 2007[67] | | Osteoradionecrosis/bone toxicity | 82 | Late, ≥ Gr 3, Δ-6, p NR | | | | | Not done
Chen et al. 2007[67] | | Local control | 82 | 5 yr., Δ+6, NS | | | | | Not done
Chen et al. 2007[67] | | Disease-free survival | 82 | NS | | | | | Not done
Chen et al. 2007[67] | | Overall survival | 82 | 5 yr., Δ-4, NS | | | | | Not done

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

Late mucositis was similar in the IMRT and 2DRT groups; late skin toxicity was less common with IMRT, and late osteoradionecrosis or bone toxicity was slightly less common in the IMRT group. The statistical significance of these IMRT-2DRT differences was not reported. Local control and overall survival was similar with IMRT and 2DCRT, while the magnitude of the difference for disease-free survival was not reported. However, none of these differences was statistically significant. No multivariable analysis was performed to account for potential confounders. This study provided insufficient evidence to draw any conclusions on the comparative effectiveness of IMRT and 2DRT among patients with nasal cavity/paranasal sinus cancer.

IMRT Versus 2DRT: Unknown Primary Cancers, Mixed Settings. A single study compared IMRT versus 2DRT among patients with unknown primary cancers. In a retrospective study Madani et al.78 compared these radiotherapy techniques among 41 patients in mixed treatment settings (Table 30).Radiotherapy was primary or postoperative; some patients received chemotherapy but the timing was unclear. The typical subject in this study was male (22–26 percent female) around 60 years old (median: 58–61 years) with advanced cancer. The primary tumor prescribed dose was 56–69 Gy for IMRT and 66 Gy for 2DRT.

Table 30 IMRT vs. 2DRT: Summary data on mixed settings for unknown primary cancers

Study | Setting | Outcome | n | Univariate p value | Multi-variable p value | Study design | Initial groups comparable? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Madani et al. 2008[78] | Primary/postoperative RT ± chemotherapy with unclear timing | Dysphagia | 41 | Acute, Gr 3, Δ-45, .003 Late, Gr 3, Δ-27, .01 | | Retrospective | No | No | Not done | Poor
| | Mucositis | 41 | Acute, Gr 3, Δ-9, NS | | | | | Not done
| | Skin toxicity | 41 | Acute, Gr 3, Δ-35, .08 Late, Gr 3, Δ-27, .03 | | | | | Not done
| | Overall survival | 41 | 1 yr., Δ+33, NS | | | | | Not done

Abbreviations: Δ: change; Gr: grade; NR: not reported; NS: not significant; RT: radiotherapy; yr: year;

Acute grade 3 dysphagia was less common in the IMRT group (4.5%) than in the 2DRT group (50 percent, p=.003). Late grade 3 dysphagia was also significantly less common, with a between-group difference of 27 percentage points (p=.01).Acute grade 3 mucositis was slightly less frequent among IMRT patients; the difference was nonsignificant. Grade 3 acute skin toxicity was lower in the IMRT group (31.7 percent versus 66.7 percent, p= .08). Late skin toxicity was significantly less common with IMRT (0 percent versus 26.7 percent, p= .03). One-year overall survival was greater with IMRT, but the difference with 2DRT was not statistically significant. None of these results have been adjusted for potential confounding factors using a multivariable analysis. This study provided insufficient evidence to draw an y conclusions on the comparative effectiveness of IMRT and 2DRT among patients with unknown primary cancers.

IMRT Versus 2DRT: Mixed Tumor Sites, Mixed Settings. Eight studies compared IMRT versus 2DRT among patients with mixed head and neck tumor sites and reported on one of the 12 key outcomes (Table 31).Gomez et al. 70 and Palazzi et al. 80 each had three arms, including IMRT to 2DRT. Six other studies30,35,39,40,64,90 compared IMRT to 2DRT alone. Two studies reported data for outcomes that are not the central focus of this review and will not be discussed here further.77,84

Table 31 IMRT vs. 2DRT: Summary data on mixed settings for mixed tumor sites

Study | Setting | Outcome | n | Univariate p value | Multi-variable p value | Study design | Initial groups comparable ? | Treatments in same time period? | Well-done multivariable analysis? | Study quality rating
Jabbari et al. 2005[30] | Primary/postoperative RT ± chemotherapy with unclear timing | Quality of life | 106 | 1/3/6/12/18/24 mos., HNQOL, total and 4 domains [underlined: IMRT]: all F/U, trend for improvement: total .04, Communication NS, Eating .07, Emotion .04, Pain .05 [underlined: 2DRT]: all F/U, trend for improvement, total and all domains NS 12-month between-group difference in total HNQOL, adjusted for baseline score NS | | Prospective | Unclear | Yes | Not done | Poor
Daly et al. 2007[39] | Primary/postoperative RT ± concurrent/chemotherapy with unclear timing | Xerostomia | 69 | [underlined: > 6 mos., U Michigan Xerostomia Questionnaire (XQ), item means] Items with statistically significant results: Talking Difficulty IMRT-.003, Chewing Difficulty IMRT-.03, Dryness with Eating IMRT-.02, Dryness without Eating IMRT-.03, Frequent Sipping when Eating IMRT-.002, Frequent Sipping when no Eating IMRT-.0006, Total IMRT-.006 Items with statistically NS results: Swallowing Difficulty, Sleeping Problems | | Retrospective | Yes | Yes | Not done | Poor
Jabbari et al. 2005[30] | | | 106 | [underlined: 1/3/6/12/18/24 mos., XQ item medians] IMRT: 6–12 mo trend for improvement .08 2DRT: trend for improvement NS 12-month between-group difference in XQ, adjusted for baseline score NS
Pacholke et al. 2005[40] | Primary/postoperative RT ± chemotherapy with unclear timing | Xerostomia | 210 | [underlined: > 1 yr. XQ total means] RT technique was significant at <.001 on multivariable analysis | | Retrospective | Unclear | Unclear | Unclear | Poor
Palazzi et al. 2008[80] | Primary/postoperative RT ± concurrent ± pre-RT chemotherapy | Xerostomia | 45 | Acute | NS | Prospective | Unclear | No | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | [underlined: Median F/U 2.6 yr, blend of EORTC QLQ-H&N35 and XQ in rest and during meals] | .008 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Less/much less saliva IMRT-, .07 | NS | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Less/much less change in saliva NS | .001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always dry not eating IMRT-, .004 | NS | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always probs w/gums NS | <.001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always probs speak IMRT-, <.0001 | .001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always drink day IMRT-, .001 | NS | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always trouble sleeping NS | .03 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always drink night IMRT-, .05 | <.001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always probs solid food IMRT-, <.001 | .001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always probs grnd food IMRT-, <.001 | <.001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always probs swallow solid IMRT-, <.001 | .02 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always probs swallow grnd IMRT-, .007 | <.001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always dry during meals IMRT-, <.001 | <.001 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always water to swallow IMRT-, <.001 | .02 | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Freq/always difficult social eating IMRT-, .006 | NS | Retrospective | Unclear | Unclear | Unclear | Poor
van Rij et al. 2008[35] | Primary/postoperative RT ± concurrent chemotherapy | Xerostomia | 162 | Ground/liquid diet .03 Swallow more freq NS | | Retrospective | Unclear | Unclear | Unclear | Poor
Palazzi et al. 2008[80] | | Dysphagia | 45 | Acute, > Gr 2 | NS
Caudell et al. 2009[64] | Primary RT ± pre-RT and/or concurrent chemotherapy | Dysphagia | 122 | Long-term PEG dependence/aspiration pneumonia/pharyngeal-esophageal stricture/stenosis, ≈ NS | NS | Retrospective | Unclear | Unclear | No | Poor
Palazzi et al. 2008[80] | | Mucositis | 45 | Acute, > Gr 2 | NS
Murphy et al. 2009[90] | | Mucositis | 75 | Acute, > mod Gr,Δ-25, NS | | Prospective | Unclear | Yes | No | Poor
Palazzi et al. 2008[80] | | Skin toxicity | 45 | Acute, > Gr 2 | NS
Gomez et al. 2008[70] | | Disease-free survival | 44 | NS | Not entered | Retrospective | Unclear | Yes | Unclear | Poor
Gomez et al. 2008[70] | | Overall survival | 44 | NS | Not entered

Abbreviations: Δ: change; Gr: grade; mos.: months; NR: not reported; NS: not significant; RT: radiotherapy; wks: weeks; yr: year;

These studies are difficult to interpret, because the impact of radiotherapy modalities on outcomes may vary by tumor site, e.g., if the tumor is adjacent to a particular critical structure. Multiple settings further complicate inferences about the data. Most did not have multivariable analyses, the analyses were not well done, or it was not clear whether they were well done. For four studies,35,40,64,80 treatment for the comparison groups either was not performed during the same era or it was unclear.

Patients were treated with primary or postoperative radiotherapy, with or without chemotherapy. Of a total of 758 subjects, the majority were male in six of the studies (one exception70 and not reported in one 40); the median age was 52–59 (age not reported in one40); and the percentage of patients with advanced cancer (stage III or IV) was 80 percent or greater in six studies (≥47.4 percent in one70 and not reported in one 40).The prescribed dose to the primary tumor ranged from a minimum of 52 Gy to a maximum of 79 Gy in all studies, except for 2DRT dose not reported in one study.39

One study30 reported quality of life, using HNQOL at 1, 3, 6, 12, 18, and 24 months (for more information on quality of life and xerostomia instruments, see Table 3 in the Methods chapter).There was a significant improvement trend for IMRT, but not for 2DRT; however, the between-group difference for the total score, adjusted for the baseline value, was not statistically significant. The University of Michigan Xerostomia Questionnaire (XQ) was used to gauge xerostomia in three studies30,39,40 and a blend of EORTC QLQ -H&N35 and XQ in one.35 Acute xerostomia was also reported for another study.80 The results were mixed, with statistically significant differences between treatment groups for some items (with IMRT results better than 2DRT) but not others. No statistically significant differences in the frequency of adverse events between IMRT and 2DRT were found for dysphagia,64,80 acute mucositis, 80,90 or acute skin toxicity.80 Only one study 70 reported patient survival outcomes, and the treatment group differences for disease-free and overall survival were not statistically significant in the univariate analysis; type of radiotherapy was not included as a factor in the multivariable analysis.

These studies of mixed head and neck cancer sites provided insufficient evidence to draw any conclusions on the comparative effectiveness of IMRT and 2DRT among these patients.

### IMRT Single-Arm Studies Summary

#### Study Overview

Two-thirds of 51 studies (total 2,292 patients) involved full-field IMRT, 33 percent (996 patients) used a split-field technique. Enrollee numbers ranged from 25 patients127 to 409, 124 with median (or mean) ages from 43 years105 to 65 years. 99 Males represented 42 to 90 percent of patients by study. Patients had tumors at a single site in 41 percent of studies, including nasopharyngeal (n=seven studies29,105,108,110,111,131,133); oropharyngeal (n=six studies95,97,101,118,125,137); paranasal sinuses (n=4 studies98–100,103); oral cavity/lip (n=two studies93,134); hypopharynx (n=one study122); and base of tongue (n=one study107). Eight studies31,106,109,112,119,130,132,135 (16 percent) included 100 percent stage III/IV, and four studies94,108,111,121 (8 percent) included recurrent disease. Two studies 29,105(4 percent) included 100 percent early stage (I/II) nasopharyngeal cases. Among the remaining 37 studies, case mixtures included 50–96 percent stage III/IV disease.

Concurrent chemoradiotherapy in 37 studies ranged from 5 percent93,134 to 100 percent31,94,102,107,109 of patients; one of the latter107 involved patients with a single tumor location (base of tongue).Primary radiotherapy was used in eight studies 29,95,104,105,111,118,126,133(16 percent), six of which29,95,105,111,118,133 involved patients with a single tumor location. Postoperative radiotherapy was used in three studies99,100,127 (6 percent), two of which99,100 involved a single tumor site (nasal cavity/paranasal sinuses). The prescribed radiotherapy dose to the primary tumor ranged from 30 Gy to 77 Gy, with a prescribed 70 Gy in 55 percent of studies. Median follow-up ranged from 9 months111 to 64 months. 132

Key Question 1. QOL questionnaire outcomes were reported in four studies29,31,37,38 (8 percent; total n=142) with a mixture of tumor locations and stages. No two studies used the same QOL scoring instrument. Xerostomia was reported in 21 studies (41 percent) studies (total n=1,072). No grade 4 xerostomia was reported. Nine studies91,102,114,115,117,119,120,128,133 (18 percent) reported grade 3 xerostomia; the balance of studies reported xerostomia grades 0, 1, or 2. Salivary gland function was assessed in six studies29,38,95,105,113,117 (12 percent).

Dysphagia was scored in 16 studies (31 percent) including a total of 820 patients. Most patients reported grades 1–3 dysphagia. No dysphagia was reported in one study133 (n=75) of primary radiotherapy for nasopharyngeal cancer. Grade 3–4 acute dysphagia was reported in one highly clinically diverse study.112 Grades 0 –4 mucositis was reported in 28 (55 percent) studies (n=1,471). Grade 4 acute mucositis was reported in five studies94,96,97,117,132 (10 percent), all of which also involved chemotherapy.

Skin-related toxicities were reported in 21 studies (41 percent) (n=1,089), the majority grades 1 and 2. One study97 reported grade 4 acute skin-related toxicity in 5 percent of patients with mostly advanced (93 percent stage III/IV) oropharyngeal cancer. Acute grade 3 –4 skin-related toxicity was reported in one study112 involving 100 percent advanced cancers.

Osteoradionecrosis and bone-related adverse events were reported in seven studies (14 percent; n=516). One grade 4 late toxicity (mandibular fracture) was reported in a single study114 of patients (n=48) with a mix of cancers; late grade 3 osteoradionecrosis was reported in another study125 of patients (n=73) with oropharyngeal cancer.

Key Question 2. Local tumor control rates were reported in 22 studies98–101,103,105,107,109,112,114,118,120–124,131,133–137(43 percent; n=1,717). Locoregional tumor control rates were reported in 12 studies97,106,108,109,119,123,125,128,133–135,137 (24 percent; n=948). Disease -free survival (DFS) was reported in 12 studies94,97–100,106,110,121,124,125,128,137 (24 percent; n=1,006). Overall survival (OS) was reported in 27 studies94,97–101,103,105–110,112,114,119,120,124,128,131–133,135–137 (53 percent; n=1,943). Disease-specific survival (DSS) was reported in seven studies100,110,112,120,121,132,134 (14 percent; n=384).

### 3DCRT Single-Arm Studies Summary

There were 18 single-arm studies involving a total of 1,761 patients, which reported outcomes using 3DCRT, 12 studies42,140,142,145–152,154 using full field and six studies138,139,141,143,144,153 using split field. Enrollment ranged from 24 patients145 to 630 patients138; the majority of studies involved less than 60 patients. Patient age ranged from 17 years153 to 99 years of age139 and the majority of participants were male. Eight studies reported outcomes for a single tumor site, including nasopharyngeal,138,141,145,153,154 oral cavity,140 paranasal sinuses,147 and larynx 42; the remaining studies involved patients with tumors in mixed sites. Five studies140,141,144,147,150 involved patients with stage 3 or 4 disease; the remainder of the studies but one included a mix of stages or it was not clear what the stage was for all patients. One study145 involved only patients with stage 2 disease.

Treatment settings were variable, with two studies using primary radiotherapy for 100% of patients.42,144 The remaining studies used chemotherapy in variable proportions, including concurrently and pre-or post -radiation. Three studies150, 152,154 involved reirradiation with 3DCRT.

Reporting of patient outcomes included adverse events, tumor control and survival. For adverse events, xerostomia was reported in six studies,42,142,145,149,151,154 salivary flow in two studies,42,139 dysphagia in three studies, 143,146,149 mucositis in nine studies, 140–142,144–147,150,152,154 skin-related events in seven studies,140,142,143,145,147,149,154 and osteoradionecrosis in one study. 154 No study reported quality of life measures.

Reporting of tumor control included local control rates in three studies145,153,154 and locoregional control in five studies.138,141,143,146,149 Survival outcomes included disease-free survival in four studies,42,141,143,145 overall survival in 12 studies, 42,141,143–147,149,150,152–,154 and disease-specific survival in one study.143

## Key Question 3. Are there differences in comparative effectiveness of IMRT, 3DCRT, 2DRT and proton beam therapy for specific patient and tumor characteristics?

The best way methodologically to answer Key Question 3 is to include interaction terms between radiotherapy modality and patient characteristics in a multivariable analysis of data from a randomized, controlled trial. A statistically significant interaction term would indicate that the impact of treatment varies with that patient characteristic. Performing this analysis in the context of a randomized controlled trial would ensure that other potential confounding factors have been taken into account and would provide the strongest evidence (level 1). The second best approach is to include such interaction terms in a well-conducted multivariable analysis of data from a nonrandomized comparative study, also accounting for potential baseline differences in treatment groups in the multivariable analysis (level 2).

The final approach, used to generate hypotheses to be confirmed in studies with stronger research designs, is to conduct multivariable analyses of single arms studies to identify factors that may influence outcomes (level 3). The drawback of this last approach is that such results cannot separate the influence of factors on outcomes regardless of treatment from any differential impact of treatment associated with specific patient characteristics. For example, advanced disease is often associated with a poorer prognosis, independent of other factors. If, hypothetically, a treatment were less effective among patients with advanced disease, patients in the study with advanced disease would have poorer outcomes from the treatment itself. Without a comparison to another treatment modality, one cannot separate whether poorer outcomes among patients with advanced disease are due to the underlying disease process or to the relative lack of effectiveness of the treatment among those patients.

Unfortunately, of the 38 comparative studies included in this review, including three randomized controlled trials, none address the issue of the interaction between radiotherapy modality and patient/disease-specific characteristics. Therefore, there are insufficient data to answer Key Question 3.

Several single-arm studies analyzed the impact of patient characteristics on outcomes; the results, summarized below, can be used for hypothesis generation.

Single-Arm IMRT Studies. Relevant univariate or multivariable analyses of prognostic factors for locoregional control, disease-free survival, overall survival, and disease-specific survival, including age, treatment, radiotherapy dose, and tumor site, stage and histology were variously reported in five97,108,110,132,134 single -arm studies (10 percent) of IMRT (n=779; Table 32). All of these analyses reported on tumor control or patient survival outcomes as the dependent variable; none evaluated factors associated with frequency of adverse events. Among the patient or tumor characteristics found to be associated with these outcomes were age, tumor site and volume, and histology. However, these analyses do not address comparative benefit of radiotherapy techniques. Further comparative studies are needed to determine whether treatment effects vary by these factors or whether these factors are prognostic regardless of radiotherapy modality.

Table 32 Summary of multivariable analyses in single-arm studies of IMRT

Study | No. Pts | Setting | Site | % Stage 0/I/II | % Stage III/IV | Outcome | Univariate Predictors | p Value | Multivariable Predictors | p Value
Lee et al., 2007[108] (07/1996–09/2005) | 105 | ReRT: 100 | MIX | | Recurrent: 100 | LRPFS | IMRT vs. non-IMRT RT dose ≥ 50 Gy vs. < 50 Gy chemotherapy vs. no chemotherapy | <.001 .001 .031 | IMRT vs. non- IMRT | .006
Lee et al., 2007[108] (07/1996–09/2005) | 105 | ReRT: 100 | MIX | | Recurrent: 100 | OS | Age Multiple recurrences prior to re-RT vs. single chemotherapy vs. no chemotherapy IMRT vs. non-IMRT PHX vs. non-NPH tumor SCC vs. other histology | .003 .016 .046 .026 <.001 .006 | RT dose ≥50 Gy vs. < 50 Gy PHX vs. NPH tumor Other tumor vs. NPH SCC vs. other histology | .043 .001 .04 .027
Yao et al., 2007[134] (05/2001–07/2005) | 55 | Primary RT: 4 Postop RT: 85 PreopRT: 2 CCRTx: 5 PreRT chemotherapy: 2 adjuvant chemotherapy: 2 | OCL | 9 | 91 | LRC | Extracapsular extension vs. not | .0277 | NR
Worden et al., 2008[132] (01/2000–11/2002) | 53 | PreRT chemotherapy: 100 | MIX | | 100 | OS | Female sex Lower KPS Higher T class Lower N class Current smoking HPV-negative tumor BOT site | < .005 < .05 < .05 < .05 < .05 < .05 < .05 | Female sex Higher T class Lower N class Current smoking HPV-negative tumor BOT site | .008,
Worden et al., 2008[132] (01/2000–11/2002) | 53 | PreRT chemotherapy: 100 | MIX | | 100 | DSS | Female sex Higher T class Lower N class Current smoking HPV-negative tumor BOT site | < .005 < .005 < .05 < .005 < .05 < .05 | Female sex Higher T class Lower N class Current smoking HPV-negative tumor BOT site | .004
Chao et al., 2004[97] (02/1997–09/2001) | 74 | Primary RT: 19 Postop RT: 58 CCRTx: 23 | OP H | 7 | 93 | DFS | Definitive IMRT vs. postop IMRT | .02 | NR
Chao et al., 2004[97] (02/1997–09/2001) | 74 | Primary RT: 19 Postop RT: 58 CCRTx: 23 | OP H | 7 | 93 | LRC | Definitive IMRT vs. postop IMRT | .02 | GTV nGTV | .03 .05
Chao et al., 2004[97] (02/1997–09/2001) | 74 | Primary RT: 19 Postop RT: 58 CCRTx: 23 | OP H | 7 | 93 | DMFS | Definitive IMRT vs. postop IMRT | .02 | GTV nGTV GTV | .03 .01 .03
Liu et al., 2003[110] (06/1999–04/2003) | 83 | Primary RT: 24 CCRTx: 76 | NP H | 37 | 63 | OS | Stage I/II vs. III/IV | .007 | Stage I/II vs. III/IV | .041
Liu et al., 2003[110] (06/1999–04/2003) | 83 | Primary RT: 24 CCRTx: 76 | NP H | 37 | 63 | OS | N0 vs. other | .046 | No vs. other | .023
Liu et al., 2003[110] (06/1999–04/2003) | 83 | Primary RT: 24 CCRTx: 76 | NP H | 37 | 63 | OS | RT dose > 76 Gy | .046 | R dose > 76 Gy | .029
Liu et al., 2003[110] (06/1999–04/2003) | 83 | Primary RT: 24 CCRTx: 76 | NP H | 37 | 63 | DFS | T1/2 vs. T3/4 | .04 | NR
Liu et al., 2003[110] (06/1999–04/2003) | 83 | Primary RT: 24 CCRTx: 76 | NP H | 37 | 63 | DSS | RT dose > 76 Gy | .01 | RT dose > 76 Gy | .020

Single-Arm 3DCRT Studies. Relevant univariate and multivariable analyses of prognostic factors for local control, locoregional control, disease-specific survival, and overall survival, including age, gender, histologic type, mean radiation dose to primary tumor, volume of tumor irradiated, tumor stage, treatment interval, lymph node metastases, and primary tumor site were variously reported in five studies138,140,143,153,154 of 3DCRT ( Table 33). All of these analyses reported on tumor control or patient survival outcomes as the dependent variable; none evaluated factors associated with frequency of adverse events. Among the patient or tumor characteristics found to be associated with these outcomes were age, stage, tumor site and volume, lactate dehydrogenase (LDH) level, and histology. However, these analyses do not address comparative benefit of radiotherapy techniques. Further comparative studies are needed to determine whether treatment effects vary by these factors or whether these factors are prognostic regardless of radiotherapy modality.

Table 33 Summary of multivariable analyses in single-arm studies of 3DCRT

Study | No. Pts | Setting | Site | % Stage 0/I/II | % Stage III/IV | Outcome | Univariate Predictors | p Value | Multivariable Predictors | p Value
Zheng et al. 2005[154] (07/97–03/03) | 86 | ReRT (100) chemotherapy unclear (53) | NPH | | ≥51 (?balance) | OS LFF MLT | Age Gender Histologic type Mean dose primary tx Volume of primary tx irradiated T stage of recurrence GTV volume of recurrence Interval from completion of first course of RT to dx of recurrence Pre-existing late toxicities from previous RT, CT, simultaneous regional recurrence and dose conformity index. | T stage and GTV for OS (p<.01), LFF (p<.01 and p=.03), and MLT (p<.01). Advanced T stage and large GTV volume were associated with poor OS and LFF and high risk of MLT. | T stage and GTV volume | T stage significant for OS (p<.01) and LFF (p=.01). GTV volume significant for MLT (p=.04).
Ikushima et al. 2008[140] (1999–2002) | 40 | Concurrent chemotherapy (100) | OC | | 100 | Survival | Age | .32 | Age | 0.39
Ikushima et al. 2008[140] (1999–2002) | 40 | Concurrent chemotherapy (100) | OC | | 100 | Survival | Sex | .53 | Sex | 0.79
Ikushima et al. 2008[140] (1999–2002) | 40 | Concurrent chemotherapy (100) | OC | | 100 | Survival | Stage | .86 | Local response to tx | 0.12
Ikushima et al. 2008[140] (1999–2002) | 40 | Concurrent chemotherapy (100) | OC | | 100 | Survival | Local response to tx | .04 | Mode of tumor invasion | 0.14
Ikushima et al. 2008[140] (1999–2002) | 40 | Concurrent chemotherapy (100) | OC | | 100 | Survival | Mode of tumor invasion | .03 | Mode of tumor invasion | 0.14
Ikushima et al. 2008[140] (1999–2002) | 40 | Concurrent chemotherapy (100) | OC | | 100 | Survival | LN mets | .01 | LN mets | 0.15
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | T stage | | Age >40 vs. ≤40 | .03
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | T3 vs. T1–T2 | .02 | LDH ≥410 vs. <410 | .002
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | T4 vs. T1–T2 | .0002 | Histology (WHO type I-II vs. III) | .002
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Primary tumor size ≥4 cm | .002 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Parapharyngeal space extension | .01 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Sphenoid floor invasion | <.0001 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Clivus marrow infiltration | .002 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Clivus cortex invasion | <.0001 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Prevertebral muscles invasion | <.0001 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Petrous bone invasion | .01 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Sphenoid sinus invasion | .001 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Foramen lacerum invasion | .001 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Foramen ovale invasion | .0003 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Cavernous sinus invasion | .0004 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Intracranial invasion | .002 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Infratemporal fossa invasion | .005 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Ethmoid sinus invasion | .006 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Hard palate invasion | .02 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Anatomic grouping #2 with two or more anatomic sites involved | <.0001 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Anatomic grouping #3 with one or more anatomic sites involved | .0001 | Anatomic site involved ≥2 vs. <2 | .0004
Cheng et al. 2006[138] (04/90–12/02) | 630 | Primary RT (#NR) Concur- rent chemotherapy (93) Adjuvant chemotherapy (76) | NPH | | ≥65.2 (?balance) | Risk of LR recurrence | Anatomic grouping #5 with one or more anatomic sites involved | .02 | Anatomic site involved ≥2 vs. <2 | .0004
Lau et al. 2006[143] (09/00–12/02) | 56 | Adjuvant chemotherapy (100) | MIX | 7.1 | 92.8 | OS | Age at dx Initial Hb Karnofsky PS Receiving <50% planned chemotherapy T and N stage Overall stage Primary tumor site | Significant “ “ “ “ NS “ | Amount of CT received N classification | Significant
Lau et al. 2006[143] (09/00–12/02) | 56 | Adjuvant chemotherapy (100) | MIX | 7.1 | 92.8 | DSS | Age at dx Initial Hb Karnofsky PS T and N stage Amount of chemotherapy received Overall stage Primary site | Significant “ “ “ NS “ “ | Amount of CT received N classification | Significant
Lau et al. 2006[143] (09/00–12/02) | 56 | Adjuvant chemotherapy (100) | MIX | 7.1 | 92.8 | LRRFS | Age at dx Karnofsky PS Amount of chemotherapy received T and N stage Initial Hb Overall stage Primary site | Significant “ “ “ NS “ “ | Amount of CT received N classification | Significant
Sze et al. 2004[153] (11/98–06/01) | 308 | Primary RT (58.4) Concur- rent chemotherapy (37.7) Neoad-juvant chemotherapy (3.9) | NPH | | ≥56.5 (?balance) | LFFR PFS OS | GTV-P (using T stage [T1–2 vs. T3–4] as a covariate, GTV-P remained an independent prognostic factor for LFFR. When adjusted for group stage, age, gender, CT and fractionation scheme=NS) | <.05 <.05 <.05

## Key Question 4: Is there variation in comparative effectiveness of IMRT, 3DCRT, 2DRT and proton beam therapy because of differences in user experience, target volume delineation, or dosimetric parameters?

As with Key Question 3, Key Question 4 would best be addressed by evaluating treatment effect interactions with respect to user experience, target volume delineation, or dosimetric parameters, ideally using data from randomized controlled trials or secondarily, from nonrandomized comparative studies while controlling for potential differences between treatment groups at baseline. Alternatively, analyses of the impact of these factors on treatment outcomes using data from single arm studies could generate hypotheses. Unfortunately, no comparative studies were found that look at the impact of user experience, target volume delineation, or dosimetric parameters on treatment outcomes.

Two single-arm studies included radiotherapy dose as one factor in a multivariable analysis to identify factors associated with tumor control or patient survival. Lee et al.108 reported that radiotherapy dose greater than 50 Gy was associated with longer overall survival in a study of treatment for patients with recurrent disease. Liu et al.110 reported that radiotherapy dose greater than 76 Gy is a predictor of overall survival as well. However, these analyses do not address predictors of variability in radiotherapy outcomes. No other studies were found that evaluated the relationship between outcomes and user experience, target volume delineation, or dosimetric parameters. Therefore, Key Question 4 cannot be answered with the evidence available at this time.

## Proton Beam Therapy

Initial review of literature search results yielded no articleson proton beam therapy that met selection criteria. Additional efforts were undertaken to identify studies, included a focused search of the literature search result, scrutiny of review article reference lists, and request for and review of bibliography compiled for the AHRQ Technical Brief, “Particle Beam Radiation Therapies for Cancer” (published September 2009 at www.effectivehealthcare.ahrq.gov/ehc/products/58/173/2009_0915_PBRT_tech_brief.pdf).

The only relevant studies identified used a combination of proton and photon therapy, which were initially excluded because they involved more than one type of radiotherapy. The selection criteria were amended to include these studies, based on expert advice from two members of TEP providing extended consultation. Despite this change, only one single-arm study met the revised selection criteria; no comparative studies were identified.

Most studies on proton beam therapy that were characterized as dealing with head and neck cancer evaluated cancers that did not meet the consensus definition of head and neck cancer used in this review. Specifically, many of these studies dealt with skull-base tumors. A number of others were treatment planning studies that did not provide data on outcomes or adverse events. The single study abstracted155 reported on 29 patients with stage II–IV squamous cell carcinoma or lymphoepithelioma oropharyngeal cancer who received accelerated photon and proton therapy. Tumor location was mixed, comprised of 55 percent base of tongue, 34 percent tonsillar, 7 percent anterior faucial pillar-retromolar trigone, and 3 percent pharyngeal wall. Total dose was 75.9 Gy, with 50.4 Gy from photons and a 25.5 Gy boost using protons. Locoregional control was 96 percent at 2 years and 88 percent at 5 years, while disease-free survival was 81 percent and 65 percent at 2 and 5 years, respectively. Fourteen percent of subjects developed metastatic disease. Severe acute mucositis was mentioned but no numbers were reported. One case each of the following grade 3 adverse events was reported: subcutaneous fibrosis, vocal cord paralysis, and epiglottitis.

Single-arm studies can at best suggest hypotheses to be tested in comparative studies, ideally randomized, controlled trials. The available evidence on proton beam therapy in head and neck cancer is further weakened by the small sample size and mix of tumor locations in the single study that met the revised selection criteria, and by the lack of additional studies. Thus, insufficient data are available on combined photon-proton treatment of head and neck cancer to draw any conclusions regarding its effectiveness or likely adverse effects.