# References

1 National Comprehensive Cancer Network (NCCN). NCCN Clinical Practice Guidelines in Oncology: Head and Neck Cancers (V.1.2009). Available at: http://www.nccn.org/professionals/physician_gls/PDF/head-and-neck.pdf. Accessed October 2009.
2 Forastiere AA. Chemotherapy in the treatment of locally advanced head and neck cancer. J Surg Oncol. 2008;97:701-707. [pmid: 18493921].
3 Burri MK, Bevan A, Roach M III. Advances in radiation therapy: conventional to 3D, to IMRT, to 4D, and beyond. CA Cancer J Clin. 2005;55:117-134. [pmid: 15761080].
4 Lee NY, Terezakis SA. Intensity-modulated radiation therapy. J Surg Oncol. 2008;97:691-696. [pmid: 18493919].
5 Mendenhall WM, Amdur RJ, Palta JR. Intensity-modulated radiotherapy in the standard management of head and neck cancer: promises and pitfalls. J Clin Oncol. 2006;24:2618-2623. [pmid: 16763274].
6 Ballivy O, Santamaria RG, Borbalas AL, et al. Clinical application of intensity-modulated radiotherapy for head and neck cancer. Clin Transl Oncol. 2008;10:407-414. [pmid: 18628069].
7 Chavaudra J, Bridler A. Definition of volumes in external radiotherapy: ICRU reports 50 and 62. Cancer Radiother. 2001;5:472-478. [pmid: 11715299].
8 Lawrence TS, Ten Haken RK, Giaccia A. DeVita VT, Lawrence TS, Rosenberg SA, editors. Principles of radiation oncology. Chapter 21. Cancer Principles and Practice of Oncology. 8th ed. Philadelphia. Lippincott Williams and Wilkins. 2008.
9 Harris RP, Helfand M, Woolf SH, et al. for the Third US Preventive Services Task Force. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
10 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
11 Carey TS, Boden SD. A critical guide to case series reports. Spine. 2003;28(15):1631-1634. [pmid: 12897483].
12 Seidenfeld J, Samson DJ, Rothenberg BM, et al. HER2 testing to manage patients with breast cancer or other solid tumors. Evidence Report/Technology Assessment No. 172. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center, under Contract No. 290-02-0026.) AHRQ Publication No. 09-E001. Rockville, MD. Agency for Healthcare Research and Quality. November. 2008.
13 Conley BA, Taube SE. Prognostic and predictive markers in cancer. Dis Markers. 2004;20(2):35-43. [pmid: 15322312].
14 McShane LM, Altman DG, Sauerbrei W, et al. for the Statistics Subcommittee of the NCI-EORTC Working Group on Cancer Diagnostics. Reporting recommendations for tumor marker prognostic studies (REMARK). J Natl Cancer Inst. 2005;97(16):1180-1184. [pmid: 16106022].
15 Altman DG. Systematic reviews of evaluations of prognostic variables. BMJ. 2001a;323(7306):224-228. [pmid: 11473921].
16 Altman DG. Egger M, Davey Smith G, Altman DG, editors. Systematic reviews of evaluations of prognostic variables. Systematic reviews in health care: Meta-analysis in context. 2nd ed. London. BMJ Books. 2001b:228-247.
17 Altman DG, Lyman GH. Methodological challenges in the evaluation of prognostic factors in breast cancer. Breast Cancer Res Treat. 1998;52:289-303. [pmid: 10066088].
18 Altman DG, Riley RD. Primer: an evidence-based approach to prognostic markers. Nat Clin Pract Oncol. 2005;2(9):466-472. [pmid: 16265015].
19 Gould Rothberg BE, Bracken MB. E-cadherin immunohistochemical expression as a prognostic factor in infiltrating ductal carcinoma of the breast: a systematic review and meta-analysis. Breast Cancer Res Treat. 2006;100(2):139-148. [pmid: 16791476].
20 Brocklehurst P, French R. The association between maternal HIV infection and perinatal outcome: a systematic review of the literature and meta-analysis. Br J Obstet Gynaecol. 1998;105:836-848. [pmid: 9746375].
21 Simon R, Altman DG. Statistical aspects of prognostic factor studies in oncology. Br J Cancer. 1994;69:979-985. [pmid: 8198989].
22 Ransohoff DF. How to improve reliability and efficiency of research about molecular markers: roles of phases, guidelines, and study design. J Clin Epidemiol. 2007;60(12):1205-1219. [pmid: 17998073].
23 Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. BMJ. 2006;333(7572):804-806. [pmid: 17038740].
24 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. [In press].
25 Guyatt GH, Oxman AD, Vist GE, et al. for the GRADE Working Group. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. 2008;336(7650):924-926. [pmid: 18436948].
26 Tubach F, Wells GA, Ravaud P, et al. Minimal clinically important difference, low disease activity state, and patient acceptable symptom state: methodological issues. J Rheumatol. 2005;32(10):2025-2029. [pmid: 16206363].
27 Streiner DL, Norman GR. Health Measurement Scales: A Practical Guide to their Development and Use. 4th ed. New York. Oxford University Press. 2008.
28 Pow EH, Kwong DL, McMillan AS, et al. Xerostomia and quality of life after intensity-modulated radiotherapy vs. conventional radiotherapy for early-stage nasopharyngeal carcinoma: initial report on a randomized controlled clinical trial. Int J Radiat Oncol Biol Phys. 2006;66(4):981-991. [pmid: 17145528].
29 McMillan AS, Pow EH, Kwong DL, et al. Preservation of quality of life after intensity-modulated radiotherapy for early-stage nasopharyngeal carcinoma: results of a prospective longitudinal study. Head Neck. 2006;28(8):712-722. [pmid: 16475203].
30 Jabbari S, Kim HM, Feng M, et al. Matched case-control study of quality of life and xerostomia after intensity-modulated radiotherapy or standard radiotherapy for head-and-neck cancer: initial report. Int J Radiat Oncol Biol Phys. 2005;63(3):725-731. [pmid: 16199308].
31 Feng FY, Kim HM, Lyden TH, et al. Intensity-modulated radiotherapy of head and neck cancer aiming to reduce dysphagia: early dose-effect relationships for the swallowing structures. Int J Radiat Oncol Biol Phys. 2007;68(5):1289-1298. [pmid: 17560051].
32 Fang FM, Tsai WL, Chen HC, et al. Intensity-modulated or conformal radiotherapy improves the quality of life of patients with nasopharyngeal carcinoma: comparisons of four radiotherapy techniques. Cancer. 2007;109(2):313-321. [pmid: 17154159].
33 Fang FM, Chien CY, Tsai WL, et al. Quality of life and survival outcome for patients with nasopharyngeal carcinoma receiving three-dimensional conformal radiotherapy vs. intensity-modulated radiotherapy—a longitudinal study. Int J Radiat Oncol Biol Phys. 2008;72(2):356-364. [pmid: 18355980].
34 Vergeer MR, Doornaert PA, Rietveld DH, et al. Intensity-modulated radiotherapy reduces radiation-induced morbidity and improves health-related quality of life: results of a nonrandomized prospective study using a standardized follow-up program. Int J Radiat Oncol Biol Phys. 2009;74(1):1-8. [pmid: 19111400].
35 van Rij CM, Oughlane-Heemsbergen WD, Ackerstaff AH, et al. Parotid gland sparing IMRT for head and neck cancer improves xerostomia related quality of life. Radiat Oncol. 2008;3:41. [pmid: 19068126].
36 Yao M, Karnell LH, Funk GF, et al. Health-related quality-of-life outcomes following IMRT versus conventional radiotherapy for oropharyngeal squamous cell carcinoma. Int J Radiat Oncol Biol Phys. 2007;69(5):1354-1360. [pmid: 17689885].
37 Dornfeld K, Simmons JR, Karnell L, et al. Radiation doses to structures within and adjacent to the larynx are correlated with long-term diet- and speech-related quality of life. Int J Radiat Oncol Biol Phys. 2007;68(3):750-757. [pmid: 17418971].
38 Scrimger R, Kanji A, Parliament M, et al. Correlation between saliva production and quality of life measurements in head and neck cancer patients treated with intensity-modulated radiotherapy. Am J Clin Oncol. 2007;30(3):271-277. [pmid: 17551304].
39 Daly ME, Lieskovsky Y, Pawlicki T, et al. Evaluation of patterns of failure and subjective salivary function in patients treated with intensity modulated radiotherapy for head and neck squamous cell carcinoma. Head Neck. 2007;29(3):211-220. [pmid: 17111429].
40 Pacholke HD, Amdur RJ, Morris CG, et al. Late xerostomia after intensity-modulated radiation therapy versus conventional radiotherapy. Am J Clin Oncol. 2005;28(4):351-358. [pmid: 16062076].
41 Kam MK, Leung SF, Zee B, et al. Prospective randomized study of intensity-modulated radiotherapy on salivary gland function in early-stage nasopharyngeal carcinoma patients. J Clin Oncol. 2007;25(31):4873-4879. [pmid: 17971582].
42 Braaksma MM, Wijers OB, van Sornsen de Koste JR, et al. Optimisation of conformal radiation therapy by intensity modulation: cancer of the larynx and salivary gland function. Radiother Oncol. 2003;66(3):291-302. [pmid: 12742269].
43 University of Washington Department of Otolaryngology/Head and Neck Surgery. University of Washington Quality of Life Scale. Available at: http://depts.washington.edu/otoweb/research/head_neck_cancer/uw_qol_scoring_instructions.pdf. Accessed October 2009.
44 European Organisation for Research and Treatment of Cancer (EORTC) Group for Research into Quality of Life. Bibliography. Available at: http://groups.eortc.be/qol/documentation_bibliography.htm. Accessed October 2009.
45 Ware JE Jr. SF-36^®^ Health Survey Update. Available at: http://www.sf-36.org/tools/SF36.shtml. Accessed October 2009.
46 Bjordal K, Ahlner-Elmqvist M, Tollesson E, et al. Development of a European Organization for Research and Treatment of Cancer quality of life questionnaire-H&N 35. J Clin Oncol. 1999;17:1008-1019. [pmid: 10071296].
47 Bjordal K, de Graeff A, Fayers PM, et al. A 12 country field study of the EORTC QLQ-C30 (version 3.0) and the head and neck cancer specific module (EORTC QLQ-H&N35) in head and neck patients. Eur J Cancer. 2000;36:1976-1807.
48 Chandu A, Smith ACH, Rogers SN. Health-related quality of life in oral cancer: A review. J Oral Maxillofac Surg. 2006;64:495-502. [pmid: 16487814].
49 Chie W-C, Hong R-L, Lai C-C, et al. Quality of life in patient of nasopharyngeal carcinoma: Validation of the Taiwan Chinese version of the EORTC QLQ-C30 and the EORTC QLQ-H&N35. Qual Life Res. 2003;12(1):93-98. [pmid: 12625522].
50 Eisbruch A, Kim HM, Terrell JE, et al. Xerostomia and its predictors following parotid-sparing irradiation of head and neck cancer. Int J Radiat Oncol Biol Phys. 2001;50:695-704. [pmid: 11395238].
51 El-Deiry M, Funk GF, Nalwa S, et al. Long-term quality of life for surgical and nonsurgical treatment of head and neck cancer. Arch Otolaryngol Head Neck Surg. 2005;131:879-885. [pmid: 16230590].
52 Jameson MJ, Hynds Karnell L, et al. First-year trends in self-reported general health predict survival in patients with head and neck cancer. Arch Otolaryngol Head Neck Surg. 2008;134(9):958-964. [pmid: 18794441].
53 Funk GF, Karnell LH, Christensen AJ, et al. Comprehensive head and neck oncology health status assessment. Head Neck. 2003;25(7):561-575. [pmid: 12808660].
54 Hjermstad MJ, Fossa SD, Bjordal K, et al. Test/retest study of the European Organization for Research and Treatment of Cancer Core Quality-of-Life Questionnaire. J Clin Oncol. 1995;13(5):1249-1254. [pmid: 7738629].
55 Johnson JT, Ferretti GA, Nethery WJ, et al. Oral pilocarpine for post-irradiation xerostomia in patients with head and neck cancer. N Engl J Med. 1993;329:390-395. [pmid: 8326972].
56 Kaasa S, Bjordal K, Aaronson N, et al. The EORTC core quality of life questionnaire (QLQ-C30): validity and reliability when analysed with patients treated with palliative radiotherapy. Eur J Cancer. 1995;31A(13–14):2260-2263. [pmid: 8652253].
57 Rogers SN, Gwanne S, Lowe D, et al. The addition of mood and anxiety domains to the University of Washington quality of life scale. Head Neck. 2002;24(6):521-529. [pmid: 12112548].
58 Ronis DL, Duffy SA, Fowler KE, et al. Changes in quality of life over 1 year in patients with head and neck cancer. Arch Otolaryngol Head Neck Surg. 2008;134:241-8. [pmid: 18347247].
59 Terrell JE. Quality of life assessment in head and neck cancer patients. Hematol Oncol Clin N Am. 1999;13(4):49-65.
60 Terrell JE, Nanavati KA, Esclamado RM, et al. Head and neck cancer-specific quality of life: Instrument validation. Arch Otolaryngol Head Neck Surg. 1997;123:1125-1132. [pmid: 9339991].
61 Vartanian JG, Carvalho AL, Yueh B, et al. Brazilian-Portuguese validation of the University of Washington Quality of Life questionnaire for patients with head and neck cancer. Head Neck. 2006;28(12):1115-1121. [pmid: 16823873].
62 Weymuller EA Jr, Alsarraf A, Yueh B, et al. Analysis of the performance characteristics of the University of Washington Quality of Life instrument and its modification (UW-QOL-R). Arch Otolaryngol Head Neck Surg. 2001;127:489-493. [pmid: 11346422].
63 Beldi D, Jereczek-Fossa BA, D’Onofrio A, et al. Role of radiotherapy in the treatment of cervical lymph node metastases from an unknown primary site: retrospective analysis of 113 patients. Int J Radiat Oncol Biol Phys. 2007;69(4):1051-1058. [pmid: 17716824].
64 Caudell JJ, Schaner PE, Meredith RF, et al. Factors associated with long-term dysphagia after definitive radiotherapy for locally advanced head-and-neck cancer. Int J Radiat Oncol Biol Phys. 2009;73(2):410-415. [pmid: 18635320].
65 Chao KS, Deasy JO, Markman J, et al. A prospective study of salivary function sparing in patients with head-and-neck cancers receiving intensity-modulated or three-dimensional radiation therapy: initial results. Int J Radiat Oncol Biol Phys. 2001;49(4):907-916. [pmid: 11240231].
66 Chao KS, Majhail N, Huang CJ, et al. Intensity-modulated radiation therapy reduces late salivary toxicity without compromising tumor control in patients with oropharyngeal carcinoma: a comparison with conventional techniques. Radiother Oncol. 2001;61(3):275-280. [pmid: 11730997].
67 Chen AM, Daly ME, Bucci MK, et al. Carcinomas of the paranasal sinuses and nasal cavity treated with radiotherapy at a single institution over five decades: are we making improvement?. Int J Radiat Oncol Biol Phys. 2007;69(1):141-147. [pmid: 17459609].
68 Dirix P, Nuyts S, Geussens Y, et al. Malignancies of the nasal cavity and paranasal sinuses: long-term outcome with conventional or three-dimensional conformal radiotherapy. Int J Radiat Oncol Biol Phys. 2007;9(4):1042-1050. [pmid: 17570610].
69 Golen M, Skladowski K, Wygoda A, et al. The influence of radiation technique on xerostomia in head and neck cancer patients: prospective study. Rep Pract Oncol Radiother. 2007;12(5):253-260.
70 Gomez DR, Hoppe BS, Wolden SL, et al. Outcomes and prognostic variables in adenoid cystic carcinoma of the head and neck: a recent experience. Int J Radiat Oncol Biol Phys. 2008;70(5):1365-1372. [pmid: 18029108].
71 Hodge CW, Bentzen SM, Wong G, et al. Are we influencing outcome in oropharynx cancer with intensity-modulated radiotherapy: an inter-era comparison. Int J Radiat Oncol Biol Phys. 2007;69(4):1032-1041. [pmid: 17967300].
72 Hsiung CY, Ting HM, Huang HY, et al. Parotid-sparing intensity-modulated radiotherapy (IMRT) for nasopharyngeal carcinoma: preserved parotid function after IMRT on quantitative salivary scintigraphy, and comparison with historical data after conventional radiotherapy. Int J Radiat Oncol Biol Phys. 2006;66(2):454-461. [pmid: 16839707].
73 Jen YM, Shih R, Lin YS, et al. Parotid gland-sparing 3-dimensional conformal radiotherapy results in less severe dry mouth in nasopharyngeal cancer patients: a dosimetric and clinical comparison with conventional radiotherapy. Radiother Oncol. 2005;75(2):204-209. [pmid: 15908027].
74 Kuhnt T, Jirsak N, Muller AC, et al. Quantitative and qualitative investigations of salivary gland function in dependence on irradiation dose and volume for reduction of xerostomia in patients with head-and-neck cancer. Strahlenther Onkol. 2005;181(8):520-528. [pmid: 16044220].
75 Laskar S, Bahl G, Muckaden M, et al. Nasopharyngeal carcinoma in children: comparison of conventional and intensity-modulated radiotherapy. Int J Radiat Oncol Biol Phys. 2008;72(3):728-736. [pmid: 18374512].
76 Lee NY, de Arruda FF, Puri DR, et al. A comparison of intensity-modulated radiation therapy and concomitant boost radiotherapy in the setting of concurrent chemotherapy for locally advanced oropharyngeal carcinoma. Int J Radiat Oncol Biol Phys. 2006;66(4):966-974. [pmid: 17145527].
77 Louise Kent M, Brennan MT, Noll JL, et al. Radiation-induced trismus in head and neck cancer patients. Supportive Care Cancer. 2008;16(3):305-309.
78 Madani I, Vakaet L, Bonte K, et al. Intensity-modulated radiotherapy for cervical lymph node metastases from unknown primary cancer. Int J Radiat Oncol Biol Phys. 2008;71(4):1158-1166. [pmid: 18258383].
79 Marchal C, Lapeyre M, Beckendorf V, et al. Preliminary results of the assessment of intensity modulated radiotherapy (IMRT) for prostatic and head and neck tumors (STIC 2001). Cancer Radiother. 2004;8(Suppl 1):S121-S127. [pmid: 15679257].
80 Palazzi M, Tomatis S, Orlandi E, et al. Effects of treatment intensification on acute local toxicity during radiotherapy for head and neck cancer: prospective observational study validating CTCAE, Version 3.0, scoring system. Int J Radiat Oncol Biol Phys. 2008;70(2):330-337. [pmid: 17881148].
81 Rades D, Fehlauer F, Wroblesky J, et al. Prognostic factors in head-and-neck cancer patients treated with surgery followed by intensity-modulated radiotherapy (IMRT), 3D-conformal radiotherapy, or conventional radiotherapy. Oral Oncol. 2007;43(6):535-543. [pmid: 17005437].
82 Rades D, Stoehr M, Meyners T, et al. Evaluation of prognostic factors and two radiation techniques in patients treated with surgery followed by radio(chemo)therapy or definitive radio(chemo)therapy for locally advanced head-and-neck cancer. Strahlenther Onkol. 2008;184(4):198-205. [pmid: 18398584].
83 Rusthoven KE, Raben D, Ballonoff A, et al. Effect of radiation techniques in treatment of oropharynx cancer. Laryngoscope. 2008;118(4):635-639. [pmid: 18176348].
84 Sanguineti G, Adapala P, Endres EJ, et al. Dosimetric predictors of laryngeal edema. Int J Radiat Oncol Biol Phys. 2007;68(3):741-749. [pmid: 17398024].
85 Wu H, Lin Q, Yu ZH, et al. Late course conformal radiotherapy combined with chemotherapy for stage III and IV a nasopharyngeal carcinoma. Zhonghua Yi Xue Za Zhi. 2005;85(25):1778-1780. [pmid: 16253169].
86 Wu Y, Chen SB, Cai CQ. Parotid dysfunction after various methods of radiotherapy for nasopharyngeal carcinoma. Zhonghua Zhong Liu Za Zhi. 2005;27(7):432-434. [pmid: 16188132].
87 Zouhair A, Azria D, Coucke P, et al. Decreased local control following radiation therapy alone in early-stage glottic carcinoma with anterior commissure extension. Strahlenther Onkol. 2004;180(2):84-90. [pmid: 14762660].
88 Nutting C, A’Hern R, Rogers MS, et al. First results of a phase III multicenter randomized controlled trial of intensity modulated (IMRT) versus conventional radiotherapy (RT) in head and neck cancer (PARSPORT: ISRCTN48243537; CRUK/03/005, abstract and presentation). Proc Am Soc Clin Oncol. 2009;27:302s.
89 Langendijk JA, Doornaert P, Rietveld DH, et al. A predictive model for swallowing dysfunction after curative radiotherapy in head and neck cancer. Radiother Oncol. 2009;90(2):189-195. [pmid: 19167120].
90 Murphy BA, Beaumont JL, Isitt J, et al. Mucositis-related morbidity and resource utilization in head and neck cancer patients receiving radiation therapy with or without chemotherapy. J Pain Symptom Manage. 2009;38(4):522-532. [pmid: 19608377].
91 Amosson CM, Teh BS, Van TJ, et al. Dosimetric predictors of xerostomia for head-and-neck cancer patients treated with the smart (simultaneous modulated accelerated radiation therapy) boost technique. Int J Radiat Oncol Biol Phys. 2003;56(1):136-144. [pmid: 12694832].
92 Anand AK, Chaudhoory AR, Shukla A, et al. Favourable impact of intensity-modulated radiation therapy on chronic dysphagia in patients with head and neck cancer. Br J Radiol. 2008;81(971):865-871. [pmid: 18941046].
93 Ben-David MA, Diamante M, Radawski JD, et al. Lack of osteoradionecrosis of the mandible after intensity-modulated radiotherapy for head and neck cancer: likely contributions of both dental care and improved dose distributions. Int J Radiat Oncol Biol Phys. 2007;68(2):396-402. [pmid: 17321069].
94 Biagioli MC, Harvey M, Roman E, et al. Intensity-modulated radiotherapy with concurrent chemotherapy for previously irradiated, recurrent head and neck cancer. Int J Radiat Oncol Biol Phys. 2007;69(4):1067-1073. [pmid: 17967302].
95 Braam PM, Terhaard CH, Roesink JM, et al. Intensity-modulated radiotherapy significantly reduces xerostomia compared with conventional radiotherapy. Int J Radiat Oncol Biol Phys. 2006;66(4):975-980. [pmid: 16965864].
96 Caglar HB, Tishler RB, Othus M, et al. Dose to larynx predicts for swallowing complications after intensity-modulated radiotherapy. Int J Radiat Oncol Biol Phys. 2008;72(4):1110-1118. [pmid: 18468812].
97 Chao KS, Ozyigit G, Blanco AI, et al. Intensity-modulated radiation therapy for oropharyngeal carcinoma: impact of tumor volume. Int J Radiat Oncol Biol Phys. 2004;59(1):43-50. [pmid: 15093897].
98 Daly ME, Chen AM, Bucci MK, et al. Intensity-modulated radiation therapy for malignancies of the nasal cavity and paranasal sinuses. Int J Radiat Oncol Biol Phys. 2007;67(1):151-157. [pmid: 17189068].
99 Dirix P, Nuyts S, Vanstraelen B, et al. Postoperative intensity-modulated radiotherapy for malignancies of the nasal cavity and paranasal sinuses. Radiother Oncol. 2007;85(3):385-391. [pmid: 17963908].
100 Duthoy W, Boterberg T, Claus F, et al. Postoperative intensity-modulated radiotherapy in sinonasal carcinoma: clinical results in 39 patients. Cancer. 2005;104(1):71-82. [pmid: 15915466].
101 Garden AS, Morrison WH, Wong PF, et al. Disease-control rates following intensity-modulated radiation therapy for small primary oropharyngeal carcinoma. Int J Radiat Oncol Biol Phys. 2007;67(2):438-444. [pmid: 17141972].
102 Guerrero Urbano T, Clark CH, et al. A phase I study of dose-escalated chemoradiation with accelerated intensity modulated radiotherapy in locally advanced head and neck cancer. Radiother Oncol. 2007;85(1):36-41. [pmid: 17709149].
103 Hoppe BS, Wolden SL, Zelefsky MJ, et al. Postoperative intensity-modulated radiation therapy for cancers of the paranasal sinuses, nasal cavity, and lacrimal glands: Technique, early outcomes, and toxicity. Head Neck. 2008;30(7):925-932. [pmid: 18302261].
104 Kuppersmith RB, Greco SC, Teh BS, et al. Intensity-modulated radiotherapy: first results with this new technology on neoplasms of the head and neck. Ear Nose Throat J. 241. 1999;78(4):238-246. 248 passim. [pmid: 10224699].
105 Kwong DL, Pow EH, Sham JS, et al. Intensity-modulated radiotherapy for early-stage nasopharyngeal carcinoma: a prospective study on disease control and preservation of salivary function. Cancer. 2004;101(7):1584-1593. [pmid: 15378492].
106 Kwong DL, Sham JS, Leung LH, et al. Preliminary results of radiation dose escalation for locally advanced nasopharyngeal carcinoma. Int J Radiat Oncol Biol Phys. 2006;64(2):374-381. [pmid: 16213105].
107 Lawson JD, Otto K, Chen A, et al. Concurrent platinum-based chemotherapy and simultaneous modulated accelerated radiation therapy for locally advanced squamous cell carcinoma of the tongue base. Head Neck. 2008;30(3):327-335. [pmid: 17657789].
108 Lee N, Chan K, Bekelman JE, et al. Salvage re-irradiation for recurrent head and neck cancer. Int J Radiat Oncol Biol Phys. 2007;68(3):731-740. [pmid: 17379449].
109 Lee NY, O’Meara W, Chan K, et al. Concurrent chemotherapy and intensity-modulated radiotherapy for locoregionally advanced laryngeal and hypopharyngeal cancers. Int J Radiat Oncol Biol Phys. 2007;69(2):459-468. [pmid: 17493769].
110 Liu MT, Hsieh CY, Chang TH, et al. Prognostic factors affecting the outcome of nasopharyngeal carcinoma. Jpn J Clin Oncol. 2003;33(10):501-508. [pmid: 14623917].
111 Lu TX, Mai WY, Teh BS, et al. Initial experience using intensity-modulated radiotherapy for recurrent nasopharyngeal carcinoma. Int J Radiat Oncol Biol Phys. 2004;58(3):682-687. [pmid: 14967420].
112 Madani I, Duthoy W, Derie C, et al. Positron emission tomography-guided, focal-dose escalation using intensity-modulated radiotherapy for head and neck cancer. Int J Radiat Oncol Biol Phys. 2007;68(1):126-135. [pmid: 17448871].
113 Meirovitz A, Murdoch-Kinch CA, Schipper M, et al. Grading xerostomia by physicians or by patients after intensity-modulated radiotherapy of head-and-neck cancer. Int J Radiat Oncol Biol Phys. 2006;66(2):445-453. [pmid: 16839705].
114 Munter MW, Thilmann C, Hof H, et al. Stereotactic intensity modulated radiation therapy and inverse treatment planning for tumors of the head and neck region: clinical implementation of the step and shoot approach and first clinical results. Radiother Oncol. 2003;66(3):313-321. [pmid: 12742271].
115 Nishimura Y, Nakamatsu K, Shibata T, et al. Importance of the initial volume of parotid glands in xerostomia for patients with head and neck cancers treated with IMRT. Jpn J Clin Oncol. 2005;35(7):375-379. [pmid: 15976068].
116 Rosenthal DI, Chambers MS, Fuller CD, et al. Beam path toxicities to non-target structures during intensity-modulated radiation therapy for head and neck cancer. Int J Radiat Oncol Biol Phys. 2008;72(3):747-755. [pmid: 18455324].
117 Saarilahti K, Kouri M, Collan J, et al. Sparing of the submandibular glands by intensity modulated radiotherapy in the treatment of head and neck cancer. Radiother Oncol. 2006;78(3):270-275. [pmid: 16564589].
118 Sanguineti G, Gunn GB, Endres EJ, et al. Patterns of locoregional failure after exclusive IMRT for oropharyngeal carcinoma. Int J Radiat Oncol Biol Phys. 2008;72(3):737-746. [pmid: 18486356].
119 Schwartz M, Vuong T, Ballivy O, et al. Accelerated radiotherapy with simultaneous integrated boost fractionation and intensity-modulated radiotherapy for advanced head and neck cancer. Otolaryngol Head Neck Surg. 2007;136(4):549-555. [pmid: 17418249].
120 Seung S, Bae J, Solhjem M, et al. Intensity-modulated radiotherapy for head-and-neck cancer in the community setting. Int J Radiat Oncol Biol Phys. 2008;72(4):1075-1081. [pmid: 18486355].
121 Studer G, Graetz KW, Glanzmann C. Outcome in recurrent head neck cancer treated with salvage-IMRT. Radiat Oncol. 2008;3(1):43. [pmid: 19091097].
122 Studer G, Lutolf UM, Davis JB, et al. IMRT in hypopharyngeal tumors. Strahlenther Onkol. 2006;182(6):331-335. [pmid: 16703288].
123 Studer G, Lutolf UM, El-Bassiouni M, et al. Volumetric staging (VS) is superior to TNM and AJCC staging in predicting outcome of head and neck cancer treated with IMRT. Acta Oncol. 2007;46(3):386-394. [pmid: 17450476].
124 Studer G, Seifert B, Glanzmann C. Prediction of distant metastasis in head neck cancer patients: Implications for induction chemotherapy and pre-treatment staging?. Strahlenther Onkol. 2008;184(11):580-585. [pmid: 19016016].
125 Studer G, Studer SP, Zwahlen RA, et al. Osteoradionecrosis of the mandible: minimized risk profile following intensity-modulated radiation therapy (IMRT). Strahlenther Onkol. 2006;182(5):283-288. [pmid: 16673062].
126 Teh BS, Mai WY, Grant WH 3rd, et al. Intensity modulated radiotherapy (IMRT) decreases treatment-related morbidity and potentially enhances tumor control. Cancer Invest. 2002;20(4):437-451. [pmid: 12094538].
127 Thorstad WL, Chao KS, Haughey B. Toxicity and compliance of subcutaneous amifostine in patients undergoing postoperative intensity-modulated radiation therapy for head and neck cancer. Semin Oncol. 2004;31(6 Suppl 18):8-12. [pmid: 15726516].
128 Vosmik M, Kordac P, Paluska P, et al. IMRT using simultaneous integrated boost (66 Gy in 6 weeks) with and without concurrent chemotherapy in head and neck cancer: toxicity evaluation. Rep Pract Oncol Radiother. 2008;13(2):86-95.
129 Vosmik M, Odrazka K, Dolezel M, et al. IMRT with the use of simultaneous integrated boost in treatment of head and neck cancer: acute toxicity evaluation. Acta Medica (Hradec Kralove). 2006;49(3):167-173. [pmid: 17117605].
130 Wendt TG, Abbasi-Senger N, Salz H, et al. 3D-conformal-intensity modulated radiotherapy with compensators for head and neck cancer: clinical results of normal tissue sparing. Radiat Oncol. 2006;1:18. [pmid: 16790059].
131 Wolden SL, Chen WC, Pfister DG, et al. Intensity-modulated radiation therapy (IMRT) for nasopharynx cancer: update of the Memorial Sloan-Kettering experience. Int J Radiat Oncol Biol Phys. 2006;64(1):57-62. [pmid: 15936155].
132 Worden FP, Kumar B, Lee JS, et al. Chemoselection as a strategy for organ preservation in advanced oropharynx cancer: response and survival positively associated with HPV16 copy number. J Clin Oncol. 2008;26(19):3138-3146. [pmid: 18474879].
133 Wu S, Xie C, Jin X, et al. Simultaneous modulated accelerated radiation therapy in the treatment of nasopharyngeal cancer: a local center's experience. Int J Radiat Oncol Biol Phys. 2006;66(4 Suppl):S40-S46.
134 Yao M, Chang K, Funk GF, et al. The failure patterns of oral cavity squamous cell carcinoma after intensity-modulated radiotherapy-the University of Iowa experience. Int J Radiat Oncol Biol Phys. 2007a;67(5):1332-1341. [pmid: 17276613].
135 Yao M, Dornfeld KJ, Buatti JM, et al. Intensity-modulated radiation treatment for head-and-neck squamous cell carcinoma--the University of Iowa experience. Int J Radiat Oncol Biol Phys. 2005;63(2):410-421. [pmid: 16168834].
136 Yao M, Hoffman HT, Chang K, et al. Is planned neck dissection necessary for head and neck cancer after intensity-modulated radiotherapy?. Int J Radiat Oncol Biol Phys. 2007b;68(3):707-713. [pmid: 17379453].
137 Yao M, Nguyen T, Buatti JM, et al. Changing failure patterns in oropharyngeal squamous cell carcinoma treated with intensity modulated radiotherapy and implications for future research. Am J Clin Oncol. 2006;29(6):606-612. [pmid: 17148999].
138 Cheng SH, Tsai SY, Horng CF, et al. A prognostic scoring system for locoregional control in nasopharyngeal carcinoma following conformal radiotherapy. Int J Radiat Oncol Biol Phys. 2006;66(4):992-1003. [pmid: 16979832].
139 Dijkema T, Terhaard CHJ, Roesink JM, et al. Large cohort dose-volume response analysis of parotid gland function after radiotherapy: intensity-modulated versus conventional radiotherapy. Int J Radiat Oncol Biol Phys. 2008;72(4):1101-1109. [pmid: 18472355].
140 Ikushima I, Korogi Y, Ishii A, et al. Superselective intra-arterial infusion chemotherapy for stage III/IV squamous cell carcinomas of the oral cavity: midterm results. Eur J Radiol. 2008;66(1):7-12. [pmid: 17604932].
141 Jian JJ, Cheng SH, Tsai SY, et al. Improvement of local control of T3 and T4 nasopharyngeal carcinoma by hyperfractionated radiotherapy and concomitant chemotherapy. Int J Radiat Oncol Biol Phys. 2002;53(2):344-352. [pmid: 12023138].
142 Kovacs AF, Schiemann M, Turowski B. Combined modality treatment of oral and oropharyngeal cancer including neoadjuvant intraarterial cisplatin and radical surgery followed by concurrent radiation and chemotherapy with weekly docetaxel—three year results of a pilot study. J Craniomaxillofac Surg. 2002;30(2):112-120. [pmid: 12069515].
143 Lau H, Brar S, Hao D, et al. Concomitant low-dose cisplatin and three-dimensional conformal radiotherapy for locally advanced squamous cell carcinoma of the head and neck: analysis of survival and toxicity. Head Neck. 2006;28(3):189-196. [pmid: 16265658].
144 Levendag P, Braaksma M, Coche E, et al. Rotterdam and Brussels CT-based neck nodal delineation compared with the surgical levels as defined by the American Academy of Otolaryngology-Head and Neck Surgery. Int J Radiat Oncol Biol Phys. 2004;58(1):113-23. [pmid: 14697428].
145 Lu JJ, Shakespeare TP, Thiagarajan A, et al. Prospective phase II trial of concomitant boost radiotherapy for stage II nasopharyngeal carcinoma: an evaluation of response and toxicity. Laryngoscope. 2005;115(5):806-810. [pmid: 15867644].
146 Ozsahin M, Betz M, Matzinger O, et al. Feasibility and efficacy of subcutaneous amifostine therapy in patients with head and neck cancer treated with curative accelerated concomitant-boost radiation therapy. Arch Otolaryngol Head Neck Surg. 2006;132(2):141-145. [pmid: 16490870].
147 Padovani L, Pommier P, Clippe SS, et al. Three-dimensional conformal radiotherapy for paranasal sinus carcinoma: clinical results for 25 patients. Int J Radiat Oncol Biol Phys. 2003;56(1):169-176. [pmid: 12694835].
148 Pan CC, Eisbruch A, Lee JS, et al. Prospective study of inner ear radiation dose and hearing loss in head-and-neck cancer patients. Int J Radiat Oncol Biol Phys. 2005;61(5):1393-1402. [pmid: 15817342].
149 Pfreundner L, Hoppe F, Willner J, et al. Induction chemotherapy with paclitaxel and cisplatin and CT-based 3D radiotherapy in patients with advanced laryngeal and hypopharyngeal carcinomas—a possibility for organ preservation. Radiother Oncol. 2003;68(2):163-170. [pmid: 12972311].
150 Pommier P, Ginestet C, Sunyach M, et al. Conformal radiotherapy for paranasal sinus and nasal cavity tumors: three-dimensional treatment planning and preliminary results in 40 patients. Int J Radiat Oncol Biol Phys. 2000;48(2):485-493. [pmid: 10974466].
151 Portaluri M, Fucilli FI, Castagna R, et al. Three-dimensional conformal radiotherapy for locally advanced (Stage II and worse) head-and-neck cancer: dosimetric and clinical evaluation. Int J Radiat Oncol Biol Phys. 2006;66(4):1036-1043. [pmid: 16750321].
152 Scorsetti M, Cerreta V, Mattana F, et al. Stereotactic and conformal radiotherapy (STRT and CFRT) as rescue treatment of relapsing head and neck carcinomas. Tumori. 2001;87(4 Suppl 1):S67-S68. [pmid: 11300031].
153 Sze WM, Lee AW, Yau TK, et al. Primary tumor volume of nasopharyngeal carcinoma: prognostic significance for local control. Int J Radiat Oncol Biol Phys. 2004;59(1):21-27. [pmid: 15093895].
154 Zheng XK, Ma J, Chen LH, et al. Dosimetric and clinical results of three-dimensional conformal radiotherapy for locally recurrent nasopharyngeal carcinoma. Radiother Oncol. 2005;75(2):197-203. [pmid: 15876464].
155 Slater JD, Yonemoto LT, Mantik DW, et al. Proton radiation for treatment of cancer of the oropharynx: early experience at Loma Linda University Medical Center using a concomitant boost technique. Int J Radiat Oncol Biol Phys. 2005;62(2):494-500. [pmid: 15890592].
156 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. Accessed December 2009.
157 Mendenhall WM, Amdur RJ, Palta JR. Intensity-modulated radiotherapy in the standard management of head and neck cancer: promises and pitfalls. J Clin Oncol. 2006;24(17):2618-2623. [pmid: 16763274].
158 Gregoire V, De Neve W, Eisbruch A, et al. Intensity-modulated radiation therapy for head and neck carcinoma. Oncologist. 2007;12(5):555-564. [pmid: 17522243].
159 Das IJ, Cheng CW, Chopra KL, et al. Intensity-modulated radiation therapy dose prescription, recording, and delivery: patterns of variability among institutions and treatment planning systems. J Natl Cancer Inst. 2008;100(5):300-307. [pmid: 18314476].
160 Davies AN, Broadley K, Beighton D. Salivary gland hypofunction in patients with advanced cancer. Oral Oncol. 2002;38(7):680-685. [pmid: 12167420].
161 Randall ME, Ibbott GS. Intensity-modulated radiation therapy for gynecologic cancers: pitfalls, hazards, and cautions to be considered. Semin Radiat Oncol. 2006;16(3):138-143. [pmid: 16814153].
162 Willins J, Kachnic L. Clinically relevant standards for intensity-modulated radiation therapy dose prescription. J Natl Cancer Inst. 2008;100(5):288-290. [pmid: 18314470].
163 Pocock SJ, Assmann SE, Enos LE, et al. Subgroup analysis, covariate adjustment and baseline comparisons in clinical trial reporting: Current practice and problems. Statist Med. 2002;21:2917-2930.
164 Moher D, Schulz KF, Altman D. The CONSORT Statement: Revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. 2001;285(15):1987-1991. [pmid: 11308435].
165 Cancer Therapy Evaluation Program, Common Terminology Criteria for Adverse Events, Version 3.0, DCTD, NCI, NIH, DHHS March 31, 2003. Available at: http://ctep.cancer.gov. Publish Date: August 9, 2006.